# 8 OVERALL OBJECTIVES

## 8.1 Primary Aim

Characterize the PK of multiple-dose IV clindamycin in overweight and obese children and adolescents.

## 8.2 Secondary Aims

1. Characterize the PK of multiple-dose oral clindamycin in overweight and obese children and adolescents.
2. Characterize the safety profile of clindamycin in overweight and obese children and adolescents.