# 6 INVESTIGATORS AND STUDY ADMINISTRATIVE STRUCTURE

## 6.1 Principal Investigators

The study was initiated at 6 sites in the United States. A list of investigators is provided in Appendix 16.1.4.

## 6.2 Administrative Structure

The following is a list of organizations that were critical to the conduct of the study:

IND SPONSOR | P. Brian Smith, MD, MPH, MHS; Professor, Department of Pediatrics; Duke Clinical Research Institute; PO Box 17969; Durham, NC 27715; Tel: ▬; Fax: ▬; E-mail: ▬
FUNDING SPONSOR | Eunice Kennedy Shriver National Institutes of Child Health and Human Development (NICHD); National Institutes of Health; ▬; 31 Center Drive; Bethesda, MD 20892
PRINCIPAL INVESTIGATOR | Michael Joseph Smith, MD, MSCE; Division of Pediatric Infectious Diseases; 571 South Floyd Street, ▬; Louisville, KY 40202; Tel: ▬; Fax: ▬; E-mail: ▬
CONTRACT RESEARCH ORGANIZATION; Project Management, Data Management, Statistical Analysis, Programming, Regulatory Submissions, Site Monitoring, Safety Monitoring and Medical Writing | The Emmes Corporation; 401 N. Washington Street, ▬; Rockville MD 20850; Tel: ▬
MEDICAL MONITOR | ▬; Chief Medical Officer; The Emmes Corporation; 401 N. Washington Street, ▬; Rockville, MD 20850; Tel: ▬; ▬
LABORATORY ASSAYS | Optimized Analytical Solutions (OpAns); 4134 S. Alston Avenue, ▬; Durham, NC 27713, USA; Tel: ▬; E-mail: ▬
PHARMACOKINETIC ANALYSIS | ▬; Assistant Professor; Division of Pharmacotherapy and Experimental Therapeutics; UNC Eshelman School of Pharmacy; University of North Carolina-Chapel Hill; 2320 Kerr Hall, ▬; Chapel Hill, NC 27599-7569; Tel: ▬; E-mail: ▬