# 14 TABLES, FIGURES, AND GRAPHS REFERRED TO BUT NOT INCLUDED IN THE TEXT

## 14.1 Study Participants

Table Number | Population | Table Title / Summary
14.1.1.1 | All Enrolled Participants | Participant Accounting and Final Study Disposition by Age/BMI Stratum
14.1.1.2 | Safety Population | Participant Enrollment by Site and Age/BMI Stratum
14.1.2.1.1 | Safety Population | Demographic Summary by Age/BMI Stratum
14.1.2.1.2 | Safety Population | Growth Parameters by Age/BMI Stratum
14.1.2.2 | Safety Population | Summary of Medical History by System Organ Class, Preferred Term and by Age/BMI Stratum
14.1.3.1 | Safety Population | Protocol Deviation Classification by Site
14.1.3.2 | Safety Population | Reason Indicated for Protocol Deviations by Site
14.1.3.3 | Safety Population | Protocol Deviation Classification by Reason Indicated

## 14.2 Dosing and Pharmacokinetic Data

Table Number | Population | Table Title / Summary
14.2.1.1 | Safety Population | Summary of Study/SOC IV Doses by Age/BMI Stratum
14.2.1.2 | Safety Population | Summary of Study/SOC PO Doses and Feeding Status by Age/BMI Stratum
14.2.2.1 | PK Population | Summary of PK Sampling for IV Doses by Age/BMI Stratum
14.2.3.1 | PK Population | Summary of PK IV Concentrations by Age/BMI Stratum

## 14.3 Safety Data

Table Number | Population | Table Title / Summary
14.3.1.1 | Safety Population | Summary of Adverse Events by Age/BMI Stratum
14.3.1.2.1 | Safety Population | Adverse Events by System Organ Class, Preferred Term and by Age/BMI Stratum
14.3.1.2.2 | Safety Population | Serious Adverse Events by System Organ Class, Preferred Term and by Age/BMI Stratum
14.3.1.3 | Safety Population | Adverse Events by System Organ Class, Preferred Term, Severity and by Age/BMI Stratum
14.3.1.4 | Safety Population | Adverse Events by System Organ Class, Preferred Term, Relationship to study medication and by Age/BMI Stratum
14.3.2.1.1; 14.3.2.1.2; 14.3.2.1.3; 14.3.2.1.4 | Safety Population | Summary of Each Clinical Laboratory Hematology Measurement by Visit and Age/BMI Stratum; (Hematocrit, Hemoglobin, Platelets, WBC)
14.3.2.2.1 - 14.3.2.2.13 | Safety Population | Summary of Each Clinical Laboratory Chemistry Measurement by Visit and Age/BMI Stratum; (Albumin, AST, ALT, Bicarbonate, Total Bilirubin, BUN, Calcium, Chloride, Creatinine, Glucose, Potassium, Total Protein, Sodium)
14.3.3 | Safety Population | Summary of Microbiology Cultures by Age/BMI Stratum
14.3.4.1 | Safety Population | Summary of Baseline Physical Examination Findings by Body System and Age/BMI Stratum
14.3.4.2 | Safety Population | Summary of Post-Treatment Physical Examination Findings by Body System and Age/BMI Stratum

## 14.4 Figures

Figure Number | Population | Table Title / Summary
14.4.1 | All Enrolled Participants | Patient Profiles showing dosing, PK sampling, PK concentration, laboratory measurements of interest, AEs
14.4.2.1–14.4.2.4 | Safety Population | Summary of Clinical Laboratory Hematology Measurement by Visit; (Hematocrit, Hemoglobin, Platelet Count, WBC)
14.4.3.1–14.4.3.13 | Safety Population | Summary of Each Clinical Laboratory Serum Chemistry Measurement by Visit; (Albumin, ALT, AST, Bicarbonate, Bilirubin, BUN, Calcium, Chloride, Creatinine, Glucose, Potassium, Total Protein, Sodium)

## 14.5 SAE Narrative

Table 14.1.1.1 Participant Accounting and Final Study Disposition by Age/BMI Stratum All Enrolled Participants

| Age 2 - <12 years | | Age 12 - < 18 years | | Total
| BMI 85th - <95th percentile | BMI ≥95th percentile | BMI 85th - <95th percentile | BMI ≥95th percentile | Total
Participants Enrolled
Total Enrolled | 4 | 3 | 4 | 12 | 23
Enrolled not Dosed^*^ | 0 | 0 | 0 | 1 | 1
Safety Population | 4 (100.0%) | 3 (100.0%) | 4 (100.0%) | 11 (100.0%) | 22 (100.0%)
PK Population | 4 (100.0%) | 3 (100.0%) | 4 (100.0%) | 10 (90.9%) | 21 (95.5%)
Participants Status
Completed Study | 4 (100.0%) | 2 (66.7%) | 3 (75.0%) | 10 (90.9%) | 19 (86.4%)
Early Termination | 0 | 1 (33.3%) | 1 (25.0%) | 1 (9.1%) | 3 (13.6%)
Reasons for Early Termination
Investigator decision | 0 | 0 | 1 (25.0%) | 1 (9.1%) | 2 (9.1%)
Consent / assent withdrawn by participant / caregiver | 0 | 1 (33.3%) | 0 | 0 | 1 (4.5%)

Note: Safety Population includes enrolled and dosed participants, all percentages are based on the Safety Population.

PK Population includes all Safety participants with at least 1 fresh plasma sample.

* Enrolled not Dosed participants were enrolled and received study procedures but never received any study doses.

Participant ▬ was mistakenly enrolled in the study screen failure segment and re-enrolled in the study active segment. The screen failure enrollment is excluded from all tables and analyses.

Table 14.1.1.2 Participant Enrollment by Site and Age/BMI Stratum Safety Population

Site | Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
Site | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
▬ | 0 | 0 | 0 | 1 (100.0%) | 1 (100.0%)
▬ | 2 (33.3%) | 0 | 1 (16.7%) | 3 (50.0%) | 6 (100.0%)
▬ | 1 (16.7%) | 2 (33.3%) | 1 (16.7%) | 2 (33.3%) | 6 (100.0%)
▬ | 1 (11.1%) | 1 (11.1%) | 2 (22.2%) | 5 (55.6%) | 9 (100.0%)

Note: N’s in the column header represent number of Safety participants in each age/BMI group for all sites.

The denominator is the total number of participants at the site.

Safety Population includes enrolled and dosed participants.

Table 14.1.2.1.1 Demographic Summary by Age/BMI Stratum Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Age (years)
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 9.4 (2.7) | 10.6 (1.4) | 14.6 (1.7) | 14.8 (1.7) | 13.2 (2.9)
Median (Min, Max) | 9.5 (6.5, 11.9) | 10.7 (9.1, 11.9) | 14.5 (12.6, 16.8) | 14.9 (12.5, 17.4) | 13.2 (6.5, 17.4)
Gender
Male | 2 (50.0%) | 3 (100.0%) | 3 (75.0%) | 10 (90.9%) | 18 (81.8%)
Female | 2 (50.0%) | 0 | 1 (25.0%) | 1 (9.1%) | 4 (18.2%)
Ethnicity
Hispanic or Latino | 1 (25.0%) | 0 | 0 | 1 (9.1%) | 2 (9.1%)
Not Hispanic or Latino | 3 (75.0%) | 2 (66.7%) | 3 (75.0%) | 10 (90.9%) | 18 (81.8%)
Not reported | 0 | 1 (33.3%) | 1 (25.0%) | 0 | 2 (9.1%)
Race
White or Caucasian | 4 (100.0%) | 2 (66.7%) | 2 (50.0%) | 10 (90.9%) | 18 (81.8%)
Black or African American | 0 | 0 | 1 (25.0%) | 1 (9.1%) | 2 (9.1%)
Not reported | 0 | 1 (33.3%) | 1 (25.0%) | 0 | 2 (9.1%)

Note: Safety Population includes enrolled and dosed participants.

Table 14.1.2.1.2 Growth Parameters by Age/BMI Stratum Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Weight (kg)
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 43.0 (16.5) | 56.8 (10.4) | 74.7 (18.4) | 100.2 (45.8) | 79.2 (40.7)
Median (Min, Max) | 42.7 (27.9, 58.9) | 52.3 (49.5, 68.7) | 78.8 (50.9, 90.2) | 101.6 (50.2, 224.0) | 72.5 (27.9, 224.0)
Weight Percentile
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 90.7 (8.5) | 97.8 (1.7) | 89.5 (10.8) | 95.6 (8.6) | 93.9 (8.5)
Median (Min, Max) | 94.0 (78.1, 96.6) | 98.7 (95.9, 98.9) | 92.4 (74.3, 99.0) | 98.6 (70.6 - >99.9) | 96.5 (70.6 - >99.9)
Height (cm)
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 143.0 (22.2) | 149.7 (4.7) | 170.7 (17.3) | 166.7 (15.9) | 160.8 (18.7)
Median (Min, Max) | 143.5 (122.5, 162.3) | 148.5 (145.7, 154.8) | 175.9 (146.1, 185.0) | 171.0 (134.4, 188.0) | 162.2 (122.5, 188.0)
Height Percentile
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 79.0 (30.6) | 85.9 (9.1) | 63.7 (37.9) | 56.4 (38.0) | 65.9 (34.2)
Median (Min, Max) | 92.2 (33.6, 98.2) | 80.8 (80.5, 96.5) | 73.0 (10.2, 98.8) | 61.9 (0.3, 96.2) | 79.1 (0.3, 98.8)
BMI
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 20.3 (1.8) | 25.2 (3.0) | 25.2 (1.7) | 35.3 (13.2) | 29.3 (11.2)
Median (Min, Max) | 20.1 (18.6, 22.4) | 23.7 (23.3, 28.7) | 25.1 (23.6, 27.1) | 32.7 (26.9, 74.0) | 27.1 (18.6, 74.0)
BMI Percentile
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 90.5 (3.6) | 97.4 (1.2) | 91.7 (3.0) | 98.3 (1.3) | 95.5 (4.0)
Median (Min, Max) | 90.8 (86.0, 94.2) | 97.6 (96.1, 98.4) | 92.1 (87.8, 94.8) | 98.9 (95.7 - >99.9) | 97.0 (86.0 - >99.9)
Waist to Hip Ratio
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 0.86 (0.05) | 0.91 (0.16) | 0.90 (0.08) | 0.99 (0.07) | 0.94 (0.09)
Median (Min, Max) | 0.87 (0.80, 0.90) | 1.00 (0.73, 1.00) | 0.90 (0.80, 1.00) | 1.00 (0.90, 1.10) | 0.94 (0.73, 1.10)
Waist (cm)
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 71.13 (9.42) | 78.83 (17.75) | 84.80 (14.11) | 108.0 (27.45) | 93.09 (26.08)
Median (Min, Max) | 69.75 (63.00, 82.00) | 79.00 (61.00, 96.50) | 83.10 (72.00, 101.0) | 104.0 (75.50, 182.5) | 94.35 (61.00, 182.5)
Hip (cm)
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 82.35 (8.95) | 86.93 (8.78) | 92.05 (9.50) | 108.7 (20.21) | 97.91 (18.89)
Median (Min, Max) | 80.75 (74.90, 93.00) | 84.00 (80.00, 96.80) | 94.20 (80.00, 99.80) | 105.5 (81.00, 160.0) | 98.15 (74.90, 160.0)

Note: Safety Population includes enrolled and dosed participants.

N is number of participants unless otherwise specified.

Table 14.1.2.2 Summary of Medical History by System Organ Class, Preferred Term and by Age/BMI Stratum All Enrolled Participants

System Organ Class; Preferred Term | Age 2 - <12 years | | | | Age 12 - <18 years | | | | All Participants; (N=22)
System Organ Class; Preferred Term | BMI 85th - <95th percentile; (N = 4) | | BMI ≥95th percentile; (N = 3) | | BMI 85th - <95th percentile; (N = 4) | | BMI ≥95th percentile; (N = 11) | | All Participants; (N=22)
System Organ Class; Preferred Term | Participants With Medical History N (%) | Total Medical History N | Participants With Medical History N (%) | Total Medical History N | Participants With Medical History N (%) | Total Medical History N | Participants With Medical History N (%) | Total Medical History N | Participants With Medical History N (%) | Total Medical History N
Blood and lymphatic system disorders | 1 (25%) | 1 | 1 (33.3%) | 2 | 0 | 0 | 2 (18.2%) | 4 | 4 (18.2%) | 7
Abdominal lymphadenopathy | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Anaemia | 1 (25%) | 1 | 1 (33.3%) | 1 | 0 | 0 | 2 (18.2%) | 2 | 4 (18.2%) | 4
Febrile neutropenia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Lymphadenopathy | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Cardiac disorders | 1 (25%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 2
Cardiomegaly | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Tachycardia | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Congenital, familial and genetic disorders | 1 (25%) | 1 | 1 (33.3%) | 1 | 0 | 0 | 1 (9.1%) | 1 | 3 (13.6%) | 3
Arteriovenous malformation | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Malformation venous | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Tourette’s disorder | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Endocrine disorders | 0 | 0 | 0 | 0 | 0 | 0 | 2 (18.2%) | 2 | 2 (9.1%) | 2
Hypothyroidism | 0 | 0 | 0 | 0 | 0 | 0 | 2 (18.2%) | 2 | 2 (9.1%) | 2
Eye disorders | 0 | 0 | 1 (33.3%) | 1 | 1 (25%) | 1 | 0 | 0 | 2 (9.1%) | 2
Conjunctivitis | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Periorbital oedema | 0 | 0 | 0 | 0 | 1 (25%) | 1 | 0 | 0 | 1 (4.5%) | 1
Gastrointestinal disorders | 2 (50%) | 2 | 2 (66.7%) | 5 | 1 (25%) | 1 | 6 (54.5%) | 8 | 11 (50%) | 16
Abdominal pain | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 2 (18.2%) | 2 | 3 (13.6%) | 3
Ascites | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Chapped lips | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Constipation | 0 | 0 | 0 | 0 | 0 | 0 | 2 (18.2%) | 2 | 2 (9.1%) | 2
Diarrhoea | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Gastrooesophageal reflux disease | 0 | 0 | 0 | 0 | 1 (25%) | 1 | 1 (9.1%) | 1 | 2 (9.1%) | 2
Irritable bowel syndrome | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Nausea | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 2 (9.1%) | 2
Oral discharge | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Strawberry tongue | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Vomiting | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
General disorders and administration site conditions | 1 (25%) | 2 | 1 (33.3%) | 2 | 1 (25%) | 1 | 2 (18.2%) | 3 | 5 (22.7%) | 8
Gait disturbance | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Malaise | 1 (25%) | 1 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 2 (9.1%) | 2
Pain | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Pyrexia | 1 (25%) | 1 | 1 (33.3%) | 1 | 1 (25%) | 1 | 1 (9.1%) | 1 | 4 (18.2%) | 4
Hepatobiliary disorders | 0 | 0 | 1 (33.3%) | 2 | 0 | 0 | 0 | 0 | 1 (4.5%) | 2
Hepatomegaly | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Hypoalbuminaemia | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Immune system disorders | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 1 (9.1%) | 1 | 2 (9.1%) | 2
Seasonal allergy | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 1 (9.1%) | 1 | 2 (9.1%) | 2
Infections and infestations | 3 (75%) | 10 | 3 (100%) | 3 | 3 (75%) | 7 | 5 (45.5%) | 8 | 14 (63.6%) | 28
Abdominal wall abscess | 0 | 0 | 0 | 0 | 1 (25%) | 1 | 0 | 0 | 1 (4.5%) | 1
Abscess | 1 (25%) | 1 | 0 | 0 | 1 (25%) | 1 | 0 | 0 | 2 (9.1%) | 2
Abscess limb | 0 | 0 | 0 | 0 | 1 (25%) | 1 | 1 (9.1%) | 1 | 2 (9.1%) | 2
Arthritis bacterial | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Cellulitis | 1 (25%) | 2 | 2 (66.7%) | 2 | 1 (25%) | 1 | 2 (18.2%) | 2 | 6 (27.3%) | 7
Folliculitis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Hordeolum | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Infectious peritonitis | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Intervertebral discitis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Lice infestation | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Osteomyelitis | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 2 (9.1%) | 2
Otitis media acute | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Pyomyositis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Sepsis | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Septic shock | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Staphylococcal infection | 1 (25%) | 1 | 0 | 0 | 2 (50%) | 3 | 0 | 0 | 3 (13.6%) | 4
Injury, poisoning and procedural complications | 0 | 0 | 0 | 0 | 0 | 0 | 2 (18.2%) | 5 | 2 (9.1%) | 5
Exposure via inhalation | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Eye burns | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Humerus fracture | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 2 | 1 (4.5%) | 2
Thermal burn | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Investigations | 0 | 0 | 0 | 0 | 0 | 0 | 2 (18.2%) | 4 | 2 (9.1%) | 4
Blood glucose increased | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Blood potassium increased | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Platelet count decreased | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Staphylococcus test | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Metabolism and nutrition disorders | 1 (25%) | 3 | 1 (33.3%) | 2 | 0 | 0 | 2 (18.2%) | 3 | 4 (18.2%) | 8
Hyperglycaemia | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Hypokalaemia | 1 (25%) | 1 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 2 (9.1%) | 2
Hyponatraemia | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Insulin resistance | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Malnutrition | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Obesity | 0 | 0 | 0 | 0 | 0 | 0 | 2 (18.2%) | 2 | 2 (9.1%) | 2
Musculoskeletal and connective tissue disorders | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 5 (45.5%) | 8 | 6 (27.3%) | 9
Arthralgia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 3 | 1 (4.5%) | 3
Back pain | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Joint contracture | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Joint range of motion decreased | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Muscular weakness | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Pain in extremity | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 2 (9.1%) | 2
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 2 | 1 (4.5%) | 2
Pineal germinoma | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 2 | 1 (4.5%) | 2
Nervous system disorders | 1 (25%) | 1 | 1 (33.3%) | 2 | 0 | 0 | 5 (45.5%) | 9 | 7 (31.8%) | 12
Cerebrospinal fluid leakage | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Convulsion | 0 | 0 | 0 | 0 | 0 | 0 | 3 (27.3%) | 3 | 3 (13.6%) | 3
Dizziness | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Dysstasia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Headache | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Hemiplegia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Hydrocephalus | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Mental retardation | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Migraine | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Paraplegia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Psychiatric disorders | 1 (25%) | 1 | 0 | 0 | 1 (25%) | 1 | 2 (18.2%) | 2 | 4 (18.2%) | 4
Anxiety | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Attention deficit/hyperactivity disorder | 0 | 0 | 0 | 0 | 1 (25%) | 1 | 1 (9.1%) | 1 | 2 (9.1%) | 2
Impulse-control disorder | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Renal and urinary disorders | 0 | 0 | 0 | 0 | 0 | 0 | 2 (18.2%) | 2 | 2 (9.1%) | 2
Hydronephrosis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Tubulointerstitial nephritis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Reproductive system and breast disorders | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Vulvovaginal erythema | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Respiratory, thoracic and mediastinal disorders | 1 (25%) | 3 | 0 | 0 | 0 | 0 | 2 (18.2%) | 3 | 3 (13.6%) | 6
Acute respiratory failure | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 2 (9.1%) | 2
Asthma | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Hypoxia | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Pleural effusion | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Tachypnoea | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Skin and subcutaneous tissue disorders | 1 (25%) | 1 | 1 (33.3%) | 2 | 0 | 0 | 4 (36.4%) | 5 | 6 (27.3%) | 8
Acanthosis nigricans | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Decubitus ulcer | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Petechiae | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Rash erythematous | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Rash macular | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Rash maculo-papular | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Rash vesicular | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Skin exfoliation | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Surgical and medical procedures | 1 (25%) | 1 | 0 | 0 | 2 (50%) | 2 | 3 (27.3%) | 3 | 6 (27.3%) | 6
Appendicectomy | 0 | 0 | 0 | 0 | 1 (25%) | 1 | 0 | 0 | 1 (4.5%) | 1
Incisional drainage | 0 | 0 | 0 | 0 | 1 (25%) | 1 | 1 (9.1%) | 1 | 2 (9.1%) | 2
Leg amputation | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Ventricular drainage | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Ventriculo-peritoneal shunt | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Vascular disorders | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 2 (18.2%) | 2 | 3 (13.6%) | 3
Hypertension | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Pelvic venous thrombosis | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Venous insufficiency | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1

Note: The percentages are based on the total number of participants in each Age/BMI stratum or total.

Participants are counted once at each System Organ Class and Preferred Term levels.

Table 14.1.3.1 Protocol Deviation Classification by Site Safety Population

Site | Study Informed Consent/Assent | | Eligibility/Enrollment | | Study Medication Administration | | Protocol Procedure/Assessment | | Unreported AE | | Total
Site | Participants with PD N (%) | Total PDs N | Participants with PD N (%) | Total PDs N | Participants with PD N (%) | Total PDs N | Participants with PD N (%) | Total PDs N | Participants with PD N (%) | Total PDs N | Participants with PD N (%) | Total PDs N
▬ | 1 (100%) | 1 | 1 (100%) | 1 | 1 (100%) | 3 | 1 (100%) | 3 | 0 | 0 | 1 (100%) | 8
▬ | 0 | 0 | 1 (16.7%) | 1 | 2 (33.3%) | 5 | 1 (16.7%) | 1 | 1 (16.7%) | 1 | 4 (66.7%) | 8
▬ | 1 (16.7%) | 1 | 0 | 0 | 2 (33.3%) | 7 | 3 (50%) | 3 | 0 | 0 | 4 (66.7%) | 11
▬ | 1 (11.1%) | 1 | 0 | 0 | 2 (22.2%) | 6 | 2 (22.2%) | 3 | 0 | 0 | 3 (33.3%) | 10
Total | 3 (13.6%) | 3 | 2 (9.1%) | 2 | 7 (31.8%) | 21 | 7 (31.8%) | 10 | 1 (4.5%) | 1 | 12 (54.5%) | 37

Note: Denominator is the number of participants enrolled at each site or total.

PD=Protocol Deviation

Safety Population includes enrolled and dosed participants.

Table 14.1.3.2 Reason Indicated for Protocol Deviations by Site Safety Population

Site | Research Staff/Clinic Error | | Hospital Error | | Pharmacy Error | | Laboratory Error | | PI Decision | | Participant Unable to Comply | | Other Reason | | Total
Site | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N
▬ | 1 (100%) | 6 | 1 (100%) | 1 | 0 | 0 | 0 | 0 | 1 (100%) | 1 | 0 | 0 | 0 | 0 | 1 (100%) | 8
▬ | 1 (16.7%) | 1 | 2 (33.3%) | 5 | 0 | 0 | 1 (16.7%) | 1 | 0 | 0 | 0 | 0 | 1 (16.7%) | 1 | 4 (66.7%) | 8
▬ | 1 (16.7%) | 2 | 1 (16.7%) | 2 | 0 | 0 | 1 (16.7%) | 1 | 0 | 0 | 1 (16.7%) | 6 | 0 | 0 | 4 (66.7%) | 11
▬ | 2 (22.2%) | 3 | 2 (22.2%) | 5 | 1 (11.1%) | 1 | 0 | 0 | 1 (11.1%) | 1 | 0 | 0 | 0 | 0 | 3 (33.3%) | 10
Total | 5 (22.7%) | 12 | 6 (27.3%) | 13 | 1 (4.5%) | 1 | 2 (9.1%) | 2 | 2 (9.1%) | 2 | 1 (4.5%) | 6 | 1 (4.5%) | 1 | 12 (54.5%) | 37

Note: Denominator is the number of participants enrolled at each site or total.

Pts=Participants, PD=Protocol Deviation

Safety Population includes enrolled and dosed participants.

Table 14.1.3.3 Protocol Deviation Classification by Reason Indicated Safety Population

Deviation Classification | Research Staff/Clinic Error | | Hospital Error | | Pharmacy Error | | Lab Error | | PI decision | | Participant Unable to Comply | | Other Reason | | Total
Deviation Classification | Pts with PD N | Total PDs N (%) | Pts with PD N | Total PDs N (%) | Pts with PD N | Total PDs N (%) | Pts with PD N | Total PDs N (%) | Pts with PD N | Total PDs N (%) | Pts with PD N | Total PDs N (%) | Pts with PD N | Total PDs N (%) | Pts with PD N | Total PDs N (%)
Informed consent/assent | 3 | 3 (100%) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3 | 3 (100%)
Eligibility/enrollment | 1 | 1 (50%) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1 (50%) | 2 | 2 (100%)
Study medication administration | 1 | 2 (9.5%) | 6 | 13 (61.9%) | 1 | 1 (4.8%) | 0 | 0 | 0 | 0 | 1 | 5 (23.8%) | 0 | 0 | 7 | 21 (100%)
Protocol procedure/assessment | 3 | 5 (50%) | 0 | 0 | 0 | 0 | 2 | 2 (20%) | 2 | 2 (20%) | 1 | 1 (10%) | 0 | 0 | 7 | 10 (100%)
Unreported AE | 1 | 1 (100%) | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1 (100%)
Total | 5 | 12 (32.4%) | 6 | 13 (35.1%) | 1 | 1 (2.7%) | 2 | 2 (5.4%) | 2 | 2 (5.4%) | 1 | 6 (16.2%) | 1 | 1 (2.7%) | 12 | 37 (100%)

Note: Denominator is the number of participants in each classification or total.

Pts=Participants, PD=Protocol Deviation

Safety Population includes enrolled and dosed participants.

Table 14.2.1.1 Summary of Study/SOC IV Doses by Age/BMI Stratum Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Number of Study Doses per Participant
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 2.5 (1.0) | 2.7 (0.6) | 3.0 (2.0) | 8.5 (8.2) | 5.6 (6.4)
Median (Min, Max) | 2.0 (2.0, 4.0) | 3.0 (2.0, 3.0) | 2.0 (2.0, 6.0) | 4.0 (2.0, 26.0) | 3.0 (2.0, 26.0)
Study Doses (mg)
N of Doses | 10 | 8 | 12 | 80 | 110
Mean (SD) | 486.0 (176.3) | 544.8 (85.5) | 787.0 (168.6) | 879.9 (186.9) | 809.6 (222.9)
Median (Min, Max) | 400.0 (300.0, 780.0) | 532.8 (470.0, 675.0) | 900.0 (522.0, 900.0) | 900.0 (502.2, 1100) | 900.0 (300.0, 1100)
Study Doses (mg/kg)
N of Doses | 10 | 8 | 12 | 80 | 110
Mean (SD) | 12.4 (2.1) | 10.0 (0.0) | 9.8 (0.6) | 9.4 (1.5) | 9.8 (1.7)
Median (Min, Max) | 13.3 (9.9, 14.3) | 10.0 (10.0, 10.0) | 10.0 (8.6, 10.3) | 10.0 (3.0, 10.5) | 10.0 (3.0, 14.3)
Dosing Frequency of Study Doses
Every 8 Hours | 8 (80.0%) | 3 (37.5%) | 10 (83.3%) | 74 (92.5%) | 95 (86.4%)
Every 6 Hours | 2 (20.0%) | 5 (62.5%) | 2 (16.7%) | 6 (7.5%) | 15 (13.6%)
Number of SOC Doses per Participant
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 3.5 (2.1) | 3.7 (1.2) | 2.3 (1.0) | 4.6 (1.3) | 3.9 (1.6)
Median (Min, Max) | 3.5 (1.0, 6.0) | 3.0 (3.0, 5.0) | 2.5 (1.0, 3.0) | 5.0 (3.0, 6.0) | 3.5 (1.0, 6.0)
SOC Doses (mg)
N of Doses | 14 | 11 | 9 | 51 | 85
Mean (SD) | 505.2 (203.8) | 580.3 (93.9) | 674.0 (172.8) | 749.5 (165.4) | 679.4 (189.6)
Median (Min, Max) | 475.0 (300.0, 780.0) | 532.8 (470.0, 675.0) | 600.0 (522.0, 900.0) | 763.2 (216.0, 1050) | 675.0 (216.0, 1050)
SOC Doses (mg/kg)
N of Doses | 14 | 11 | 9 | 51 | 85
Mean (SD) | 11.8 (1.8) | 10.0 (0.0) | 9.6 (0.8) | 8.5 (2.1) | 9.4 (2.2)
Median (Min, Max) | 10.8 (9.9, 14.3) | 10.0 (10.0, 10.0) | 10.0 (8.6, 10.3) | 9.2 (1.0, 10.1) | 10.0 (1.0, 14.3)
Dosing Frequency of SOC Doses
Every 8 Hours | 11 (78.6%) | 3 (27.3%) | 6 (66.7%) | 41 (80.4%) | 61 (71.8%)
Every 6 Hours | 3 (21.4%) | 8 (72.7%) | 3 (33.3%) | 9 (17.6%) | 23 (27.1%)
Other | 0 | 0 | 0 | 1 (2.0%) | 1 (1.2%)

Note: Dose in mg/kg uses participant’s dosing weight.

Standard of Care is abbreviated as SOC.

Study dose includes SOC PK doses.

Safety Population includes enrolled and dosed participants.

N is number of participants unless otherwise specified.

Table 14.2.1.2 Summary of Study PO Doses by Age/BMI Stratum Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Number of Study Doses per Participant
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | 13.0 | 13.0
Median (Min, Max) | | | | 13.0 | 13.0
Study Doses (mg)
N of Doses | 0 | 0 | 0 | 13 | 13
Mean (SD) | | | | 300.0 (0.0) | 300.0 (0.0)
Median (Min, Max) | | | | 300.0 (300.0, 300.0) | 300.0 (300.0, 300.0)
Study Doses (mg/kg)
N of Doses | 0 | 0 | 0 | 13 | 13
Mean (SD) | | | | 1.3 (0.0) | 1.3 (0.0)
Median (Min, Max) | | | | 1.3 (1.3, 1.3) | 1.3 (1.3, 1.3)
Dosing Frequency of Study Doses
Every 8 Hours | | | | 13 (100.0%) | 13 (100.0%)

Note: Dose in mg/kg uses participant’s dosing weight.

Safety Population includes enrolled and dosed participants.

N is number of participants unless otherwise specified.

Table 14.2.2.1 Summary of PK Sampling for IV Doses by Age/BMI Stratum PK Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 21)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 10) | Total; (N = 21)
Total Number of PK Samples Per Participant
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 5.5 (0.6) | 2.7 (1.5) | 4.0 (1.8) | 4.5 (1.1) | 4.3 (1.4)
Median (Min, Max) | 5.5 (5.0, 6.0) | 3.0 (1.0, 4.0) | 4.0 (2.0, 6.0) | 4.0 (3.0, 6.0) | 4.0 (1.0, 6.0)
Number of Fresh Plasma Samples Per Participant
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 5.0 (0.8) | 2.7 (1.5) | 4.0 (1.8) | 4.5 (1.1) | 4.2 (1.4)
Median (Min, Max) | 5.0 (4.0, 6.0) | 3.0 (1.0, 4.0) | 4.0 (2.0, 6.0) | 4.0 (3.0, 6.0) | 4.0 (1.0, 6.0)
Number of scavenged-EDTA Plasma Samples Per Participant
N | 1 | 0 | 0 | 0 | 1
Mean (SD) | 2.0 | | | | 2.0
Median (Min, Max) | 2.0 | | | | 2.0
Type of PK Samples
Total Samples | 22 | 8 | 16 | 45 | 91
Plasma (fresh) | 20 | 8 | 16 | 45 | 89
Plasma (scavenged-EDTA) | 2 | 0 | 0 | 0 | 2

Note: PK Population includes all participants with at least 1 fresh plasma sample.

Table 14.2.3.1 Summary of PK Concentration Results by Age/BMI Stratum PK Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 21)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 10) | Total; (N = 21)
Total Number of Concentrations Measurements Per Participant
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 5.5 (0.6) | 2.7 (1.5) | 4.0 (1.8) | 4.5 (1.1) | 4.3 (1.4)
Median (Min, Max) | 5.5 (5.0, 6.0) | 3.0 (1.0, 4.0) | 4.0 (2.0, 6.0) | 4.0 (3.0, 6.0) | 4.0 (1.0, 6.0)
Type of PK Samples
Total Samples | 22 | 8 | 16 | 45 | 91
Plasma (fresh) | 20 | 8 | 16 | 45 | 89
Plasma (scavenged-EDTA) | 2 | 0 | 0 | 0 | 2
Clindamycin Concentration (ng/mL) of Fresh Plasma Samples
N of samples | 20 | 8 | 16 | 45 | 89
Mean (SD) | 7.0 (6.0) | 6.6 (3.9) | 5.3 (3.8) | 8.4 (5.0) | 7.4 (5.1)
Median (Min, Max) | 5.5 (0.3, 24.6) | 5.5 (1.9, 13.8) | 4.1 (1.2, 13.4) | 7.1 (0.7, 18.3) | 6.4 (0.3, 24.6)
Clindamycin Concentration (ng/mL) of Scavanged Plasma Samples
N of samples | 2 | 0 | 0 | 0 | 2
Mean (SD) | 8.0 (9.0) | | | | 8.0 (9.0)
Median (Min, Max) | 8.0 (1.6, 14.4) | | | | 8.0 (1.6, 14.4)

Note: PK Population includes all participants with at least 1 fresh plasma sample.

N is number of participants unless otherwise specified.

Table 14.3.1.1 Summary of Adverse Events by Age/BMI Stratum Safety Population

| Age 2 - <12 years | | Age 12 - <18 yeasr | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Number of Events/Participants
Number of Adverse Events | 1 | 0 | 0 | 2 | 3
Participants with at least one AE | 1 (25.0%) | 0 | 0 | 1 (9.1%) | 2 (9.1%)
Number of SAEs | 1 | 0 | 0 | 0 | 1
Participants with at least one SAE | 1 (25.0%) | 0 | 0 | 0 | 1 (4.5%)
Severity (All AEs)
Moderate | 0 | 0 | 0 | 2 | 2
Severe | 1 | 0 | 0 | 0 | 1
Highest Severity Per Participant
Moderate | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)
Severe | 1 (25.0%) | 0 | 0 | 0 | 1 (4.5%)
Relationship (All AEs)
Not Related | 1 | 0 | 0 | 2 | 3
Strongest Relationship Per Participant
Not Related | 1 (25.0%) | 0 | 0 | 1 (9.1%) | 2 (9.1%)
Severity (All SAEs)
Severe | 1 | 0 | 0 | 0 | 1
Relationship (All SAEs)
Not Related | 1 | 0 | 0 | 0 | 1

Note: Safety Population includes enrolled and dosed participants.

Table 14.3.1.2.1 Adverse Events by System Organ Class, Preferred Term and by Age/BMI Stratum Safety Population

System Organ Class; Preferred Term | Age 2 - <12 years | | | | Age 12 - < 18 years | | | | Total; (N=22)
System Organ Class; Preferred Term | BMI 85th - < 95th percentile; (N = 4) | | BMI >= 95th percentile; (N = 3) | | BMI 85th - < 95th percentile; (N = 4) | | BMI >= 95th percentile; (N = 11) | | Total; (N=22)
System Organ Class; Preferred Term | Pts with Event N (%) | Total Events N | Pts with Event N (%) | Total Events N | Pts with Event N (%) | Total Events N | Pts with Event N (%) | Total Events N | Pts with Event N (%) | Total Events N
Respiratory, thoracic and mediastinal disorders | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Apnoea | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Skin and subcutaneous tissue disorders | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Rash | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Vascular disorders | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1
Jugular vein thrombosis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 1 (4.5%) | 1

Note: Safety Population includes enrolled and dosed participants.

Table 14.3.1.2.2 Serious Adverse Events by System Organ Class, Preferred Term and Age/BMI Stratum Safety Population

System Organ Class; Preferred Term | Age 2 - <12 years | | | | Age 12 - < 18 years | | | | Total; (N=22)
System Organ Class; Preferred Term | BMI 85th - < 95th percentile; (N = 4) | | BMI >= 95th percentile; (N = 3) | | BMI 85th - < 95th percentile; (N = 4) | | BMI >= 95th percentile; (N = 11) | | Total; (N=22)
System Organ Class; Preferred Term | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N | Participants with Event N (%) | Total Events N
Respiratory, thoracic and mediastinal disorders | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1
Apnoea | 1 (25%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (4.5%) | 1

Note: Safety Population includes enrolled and dosed participants.

Table 14.3.1.3 Adverse Events by System Organ Class, Preferred Term, Severity and Age/BMI Stratum Safety Population

System Organ Class; Preferred Term | Severity | Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
System Organ Class; Preferred Term | Severity | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI >95th percentile; (N = 11) | Total; (N = 22)
Respiratory, thoracic and mediastinal disorders | Severe | 1 (25.0%) | 0 | 0 | 0 | 1 (4.5%)
Apnoea | Severe | 1 (25.0%) | 0 | 0 | 0 | 1 (4.5%)
Skin and subcutaneous tissue disorders | Moderate | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)
Rash | Moderate | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)
Vascular disorders | Moderate | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)
Jugular vein thrombosis | Moderate | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)

Note: The percentages are based on the total number of participants in each Age/BMI stratum or total.

Participants are counted once at each System Organ Class and Preferred Term levels using the highest severity.

Safety Population includes enrolled and dosed participants.

Table 14.3.1.4 Adverse Events by System Organ Class, Preferred Term, Relationship to Study Medication and BMI/Age Stratum Safety Population

System Organ Class; Preferred Term | Relationship | Age 2 - <12 years | | Age 12 - <18 years | | Total; (N = 22)
System Organ Class; Preferred Term | Relationship | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Respiratory, thoracic and mediastinal disorders | Not Related | 1 (25.0%) | 0 | 0 | 0 | 1 (4.5%)
Apnoea | Not Related | 1 (25.0%) | 0 | 0 | 0 | 1 (4.5%)
Skin and subcutaneous tissue disorders | Not Related | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)
Rash | Not Related | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)
Vascular disorders | Not Related | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)
Jugular vein thrombosis | Not Related | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)

Note: The percentages are based on the total number of participants in each BMI/Age Stratum or total.

Participants are counted once at each System Organ Class and Preferred Term levels using the closest relationship to study drug.

Safety Population includes enrolled and dosed participants.

Table 14.3.2.1.1 Summary of Clinical Laboratory Hematology Measurement by Visit, Age/BMI Stratum Hematocrit (%) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 32.5 (4.5) | 35.3 (6.2) | 38.3 (3.5) | 34.3 (5.6) | 34.9 (5.1)
Median (Min, Max) | 33.9 (26.0, 36.4) | 37.9 (28.3, 39.8) | 38.5 (33.8, 42.3) | 34.8 (24.3, 41.0) | 35.8 (24.3, 42.3)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 23.6 | | 28.3 (3.9) | 26.8 (3.9)
Median (Min, Max) | | 23.6 | | 28.3 (25.6, 31.1) | 25.6 (23.6, 31.1)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 28.0 (4.7) | 37.3 (1.6) | 39.0 (3.2) | 34.5 (4.6) | 34.7 (5.2)
Median (Min, Max) | 26.4 (24.4, 33.3) | 37.3 (36.2, 38.4) | 38.7 (35.6, 43.2) | 35.2 (25.0, 41.0) | 35.6 (24.4, 43.2)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 21.5 | | | 28.8 (5.8) | 26.4 (5.9)
Median (Min, Max) | 21.5 | | | 28.8 (24.7, 32.9) | 24.7 (21.5, 32.9)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.1.2 Summary of Clinical Laboratory Hematology Measurement by Visit, Age/BMI Stratum Hemoglobin (g/dL) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 10.9 (1.4) | 12.1 (1.8) | 13.4 (1.7) | 11.5 (2.0) | 11.8 (1.9)
Median (Min, Max) | 11.2 (8.9, 12.3) | 12.8 (10.1, 13.4) | 13.5 (11.2, 15.4) | 12.0 (8.1, 13.8) | 12.3 (8.1, 15.4)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 8.2 | | 9.8 (1.2) | 9.2 (1.2)
Median (Min, Max) | | 8.2 | | 9.8 (8.9, 10.6) | 8.9 (8.2, 10.6)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 9.3 (1.2) | 12.5 (0.4) | 13.1 (1.6) | 11.7 (1.6) | 11.7 (1.8)
Median (Min, Max) | 9.1 (8.2, 10.6) | 12.5 (12.2, 12.8) | 12.8 (11.6, 15.2) | 11.8 (8.6, 14.3) | 12.0 (8.2, 15.2)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 7.1 | | | 9.9 (2.1) | 8.9 (2.2)
Median (Min, Max) | 7.1 | | | 9.9 (8.4, 11.3) | 8.4 (7.1, 11.3)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.1.3 Summary of Clinical Laboratory Hematology Measurement by Visit, Age/BMI Stratum Platelet Count (10^3^/μL) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 295 (108) | 253 (62) | 237 (61) | 211 (131) | 238 (107)
Median (Min, Max) | 257 (212, 454) | 237 (201, 321) | 221 (183, 324) | 178 (30, 449) | 225 (30, 454)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 223 | | 151 (82) | 175 (71)
Median (Min, Max) | | 223 | | 151 (93, 209) | 209 (93, 223)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 315 (92) | 268 (62) | 251 (73) | 263 (135) | 269 (109)
Median (Min, Max) | 345 (212, 388) | 268 (224, 311) | 232 (188, 353) | 290 (19, 541) | 273 (19, 541)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 659 | | | 220 (250) | 366 (309)
Median (Min, Max) | 659 | | | 220 (43, 396) | 396 (43, 659)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.1.4 Summary of Clinical Laboratory Hematology Measurement by Visit, Age/BMI Stratum White Blood Count (10^3^/μL) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 11.6 (4.7) | 16.6 (3.9) | 18.0 (12.6) | 8.7 (4.7) | 12.2 (7.4)
Median (Min, Max) | 10.0 (8.0, 18.5) | 14.7 (14.0, 21.0) | 13.3 (9.0, 36.3) | 8.5 (0.2, 18.6) | 9.7 (0.2, 36.3)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 19.3 | | 13.2 (1.4) | 15.2 (3.7)
Median (Min, Max) | | 19.3 | | 13.2 (12.2, 14.2) | 14.2 (12.2, 19.3)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 11.3 (6.4) | 8.5 (1.1) | 8.9 (1.0) | 7.7 (4.0) | 8.5 (3.8)
Median (Min, Max) | 12.2 (4.4, 17.2) | 8.5 (7.7, 9.2) | 8.6 (8.1, 10.4) | 7.0 (0.3, 14.6) | 8.2 (0.3, 17.2)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 12.8 | | | 6.9 (9.1) | 8.9 (7.3)
Median (Min, Max) | 12.8 | | | 6.9 (0.5, 13.3) | 12.8 (0.5, 13.3)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.1 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Albumin (g/dL) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 3.5 (1.0) | 3.6 (1.0) | 4.1 (0.3) | 3.6 (0.8) | 3.7 (0.8)
Median (Min, Max) | 3.7 (2.1, 4.4) | 3.7 (2.6, 4.5) | 4.2 (3.7, 4.4) | 3.5 (2.3, 4.7) | 3.7 (2.1, 4.7)
During study treatment (days 1–14)
N | 0 | 0 | 0 | 2 | 2
Mean (SD) | | | | 2.8 (0.5) | 2.8 (0.5)
Median (Min, Max) | | | | 2.8 (2.4, 3.1) | 2.8 (2.4, 3.1)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 3.4 (0.3) | 3.9 (0.2) | 4.0 (0.4) | 3.6 (0.5) | 3.7 (0.4)
Median (Min, Max) | 3.4 (3.1, 3.6) | 3.9 (3.7, 4.0) | 4.1 (3.4, 4.4) | 3.6 (2.6, 4.2) | 3.6 (2.6, 4.4)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 3.7 | | | 3.7 (0.8) | 3.7 (0.6)
Median (Min, Max) | 3.7 | | | 3.7 (3.1, 4.2) | 3.7 (3.1, 4.2)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.2 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Alanine Aminotransferase ALT (U/L) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 37 (29) | 59 (47) | 17 (8) | 31 (16) | 33 (25)
Median (Min, Max) | 28 (14, 78) | 33 (31, 114) | 14 (11, 27) | 27 (10, 67) | 27 (10, 114)
During study treatment (days 1–14)
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | 65 | 65
Median (Min, Max) | | | | 65 | 65
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 29 (11) | 29 (3) | 27 (8) | 31 (13) | 30 (11)
Median (Min, Max) | 32 (16, 38) | 29 (27, 31) | 27 (18, 35) | 30 (10, 51) | 31 (10, 51)
Post treatment follow-up
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | 30 | 30
Median (Min, Max) | | | | 30 | 30

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.3 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Aspartate Aminotransferase AST (U/L) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 41 (21) | 67 (73) | 24 (9) | 24 (10) | 33 (30)
Median (Min, Max) | 34 (25, 70) | 28 (22, 151) | 25 (14, 33) | 23 (8, 40) | 25 (8, 151)
During study treatment (days 1–14)
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | 43 | 43
Median (Min, Max) | | | | 43 | 43
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 30 (5) | 31 (7) | 24 (9) | 22 (8) | 25 (8)
Median (Min, Max) | 28 (27, 36) | 31 (26, 36) | 21 (17, 36) | 23 (7, 35) | 24 (7, 36)
Post treatment follow-up
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | 27 | 27
Median (Min, Max) | | | | 27 | 27

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.4 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Bicarbonate (mEq/L) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 24 (1) | 26 (2) | 21 (4) | 26 (5) | 25 (4)
Median (Min, Max) | 24 (23, 24) | 25 (25, 28) | 22 (15, 24) | 26 (18, 35) | 24 (15, 35)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 19 | | 26 (5) | 24 (6)
Median (Min, Max) | | 19 | | 26 (22, 30) | 22 (19, 30)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 22 (3) | 26 (1) | 25 (2) | 25 (4) | 25 (4)
Median (Min, Max) | 22 (19, 26) | 26 (25, 27) | 25 (22, 27) | 26 (14, 32) | 25 (14, 32)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 25 | | | 29 (4) | 27 (3)
Median (Min, Max) | 25 | | | 29 (26, 31) | 26 (25, 31)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.5 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Total Bilrubin (mg/dL) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 9 | 20
Mean (SD) | 0.6 (0.1) | 1.5 (2.0) | 0.6 (0.2) | 0.8 (0.8) | 0.8 (0.9)
Median (Min, Max) | 0.6 (0.4, 0.7) | 0.5 (0.3, 3.8) | 0.6 (0.3, 0.7) | 0.6 (0.2, 2.8) | 0.6 (0.2, 3.8)
During study treatment (days 1–14)
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | 2.8 | 2.8
Median (Min, Max) | | | | 2.8 | 2.8
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 0.4 (0.3) | 0.6 (0.1) | 0.3 (0.2) | 0.4 (0.2) | 0.4 (0.2)
Median (Min, Max) | 0.2 (0.2, 0.7) | 0.6 (0.5, 0.7) | 0.3 (0.1, 0.5) | 0.4 (0.1, 0.7) | 0.4 (0.1, 0.7)
Post treatment follow-up
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | 0.5 | 0.5
Median (Min, Max) | | | | 0.5 | 0.5

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.6 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Blood Urea Nitrogen (mg/dL) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 10 (5) | 9 (2) | 11 (5) | 12 (5) | 11 (4)
Median (Min, Max) | 8 (6, 16) | 10 (7, 11) | 9 (8, 18) | 11 (7, 21) | 10 (6, 21)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 5 | | 20 (13) | 15 (13)
Median (Min, Max) | | 5 | | 20 (11, 29) | 11 (5, 29)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 8 (4) | 13 (5) | 12 (1) | 12 (5) | 12 (5)
Median (Min, Max) | 10 (4, 11) | 13 (9, 16) | 12 (11, 13) | 12 (6, 21) | 11 (4, 21)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 10 | | | 16 (8) | 14 (6)
Median (Min, Max) | 10 | | | 16 (10, 21) | 10 (10, 21)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.7 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Calcium (mg/dL) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 9.0 (0.9) | 9.0 (1.0) | 9.4 (0.3) | 8.9 (0.7) | 9.0 (0.7)
Median (Min, Max) | 9.1 (7.8, 9.9) | 9.1 (8.0, 9.9) | 9.5 (9.0, 9.5) | 9.0 (7.4, 9.8) | 9.1 (7.4, 9.9)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 7.2 | | 8.4 (1.2) | 8.0 (1.1)
Median (Min, Max) | | 7.2 | | 8.4 (7.5, 9.2) | 7.5 (7.2, 9.2)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 8.6 (0.3) | 9.4 (0.3) | 9.4 (0.3) | 9.1 (0.6) | 9.1 (0.5)
Median (Min, Max) | 8.7 (8.3, 8.9) | 9.4 (9.2, 9.6) | 9.3 (9.1, 9.7) | 9.0 (7.7, 9.9) | 9.2 (7.7, 9.9)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 9.1 | | | 9.9 (0.3) | 9.6 (0.5)
Median (Min, Max) | 9.1 | | | 9.9 (9.7, 10.1) | 9.7 (9.1, 10.1)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.8 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Chloride (mEq/L) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 101 (7) | 101 (7) | 102 (5) | 103 (5) | 102 (5)
Median (Min, Max) | 101 (91, 109) | 102 (93, 107) | 103 (95, 106) | 101 (98, 114) | 102 (91, 114)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 108 | | 102 (8) | 104 (7)
Median (Min, Max) | | 108 | | 102 (96, 108) | 108 (96, 108)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 105 (5) | 104 (3) | 101 (2) | 103 (4) | 103 (3)
Median (Min, Max) | 103 (101, 110) | 104 (102, 106) | 102 (99, 103) | 102 (99, 112) | 102 (99, 112)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 100 | | | 103 (6) | 102 (5)
Median (Min, Max) | 100 | | | 103 (98, 107) | 100 (98, 107)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.9 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Creatinine (mg/dL) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 0.42 (0.18) | 0.41 (0.10) | 0.70 (0.16) | 0.72 (0.32) | 0.62 (0.28)
Median (Min, Max) | 0.41 (0.24, 0.63) | 0.40 (0.31, 0.51) | 0.71 (0.50, 0.90) | 0.60 (0.40, 1.54) | 0.60 (0.24, 1.54)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 0.30 | | 1.06 (0.88) | 0.80 (0.76)
Median (Min, Max) | | 0.30 | | 1.06 (0.43, 1.68) | 0.43 (0.30, 1.68)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 0.39 (0.09) | 0.47 (0.04) | 0.60 (0.14) | 0.64 (0.18) | 0.58 (0.17)
Median (Min, Max) | 0.40 (0.30, 0.48) | 0.47 (0.44, 0.50) | 0.66 (0.40, 0.70) | 0.65 (0.40, 0.95) | 0.58 (0.30, 0.95)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 0.30 | | | 0.65 (0.21) | 0.53 (0.25)
Median (Min, Max) | 0.30 | | | 0.65 (0.50, 0.80) | 0.50 (0.30, 0.80)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.10 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Glucose (mg/dL) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 115 (26) | 101 (18) | 151 (41) | 111 (20) | 118 (29)
Median (Min, Max) | 109 (91, 151) | 99 (85, 120) | 152 (108, 192) | 106 (85, 155) | 108 (85, 192)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 94 | | 128 (9) | 117 (20)
Median (Min, Max) | | 94 | | 128 (122, 134) | 122 (94, 134)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 122 (24) | 87 (4) | 95 (10) | 100 (11) | 101 (16)
Median (Min, Max) | 135 (94, 138) | 87 (84, 89) | 94 (83, 107) | 100 (87, 125) | 96 (83, 138)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 100 | | | 106 (1) | 104 (3)
Median (Min, Max) | 100 | | | 106 (105, 106) | 105 (100, 106)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.11 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Potassium (mEq/L) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 3.6 (0.6) | 3.8 (0.7) | 4.5 (0.3) | 3.8 (0.4) | 3.9 (0.5)
Median (Min, Max) | 3.8 (2.8, 4.1) | 4.1 (3.0, 4.3) | 4.5 (4.0, 4.8) | 3.8 (3.1, 4.3) | 4.0 (2.8, 4.8)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 3.6 | | 3.9 (0.7) | 3.8 (0.5)
Median (Min, Max) | | 3.6 | | 3.9 (3.4, 4.3) | 3.6 (3.4, 4.3)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 3.9 (0.5) | 4.9 (0.8) | 4.3 (0.4) | 4.1 (0.3) | 4.2 (0.5)
Median (Min, Max) | 4.1 (3.4, 4.3) | 4.9 (4.3, 5.5) | 4.2 (4.0, 4.8) | 4.0 (3.5, 4.6) | 4.1 (3.4, 5.5)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 4.2 | | | 4.5 (0.2) | 4.4 (0.2)
Median (Min, Max) | 4.2 | | | 4.5 (4.3, 4.6) | 4.3 (4.2, 4.6)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.12 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Total Protein (g/dL) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 6.2 (1.3) | 6.9 (1.2) | 7.3 (0.5) | 6.7 (1.1) | 6.8 (1.1)
Median (Min, Max) | 6.5 (4.3, 7.4) | 6.8 (5.8, 8.1) | 7.4 (6.7, 7.8) | 6.6 (4.9, 8.4) | 6.7 (4.3, 8.4)
During study treatment (days 1–14)
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | 4.9 | 4.9
Median (Min, Max) | | | | 4.9 | 4.9
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 6.2 (0.9) | 7.2 (0.5) | 7.0 (0.3) | 6.8 (0.7) | 6.8 (0.7)
Median (Min, Max) | 6.2 (5.4, 7.1) | 7.2 (6.8, 7.5) | 7.0 (6.6, 7.4) | 6.7 (5.7, 7.8) | 6.8 (5.4, 7.8)
Post treatment follow-up
N | 0 | 0 | 0 | 1 | 1
Mean (SD) | | | | 6.6 | 6.6
Median (Min, Max) | | | | 6.6 | 6.6

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.2.2.13 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age/BMI Stratum Sodium (mEq/L) Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Baseline pre-study dose
N | 4 | 3 | 4 | 10 | 21
Mean (SD) | 138 (5) | 138 (7) | 140 (3) | 140 (4) | 139 (4)
Median (Min, Max) | 138 (132, 144) | 142 (130, 142) | 141 (137, 143) | 140 (135, 146) | 140 (130, 146)
During study treatment (days 1–14)
N | 0 | 1 | 0 | 2 | 3
Mean (SD) | | 139 | | 139 (2) | 139 (1)
Median (Min, Max) | | 139 | | 139 (137, 140) | 139 (137, 140)
End of study dose/Early termination
N | 3 | 2 | 4 | 11 | 20
Mean (SD) | 139 (0) | 142 (1) | 140 (1) | 141 (3) | 140 (2)
Median (Min, Max) | 139 (139, 140) | 142 (141, 143) | 140 (138, 141) | 141 (135, 144) | 140 (135, 144)
Post treatment follow-up
N | 1 | 0 | 0 | 2 | 3
Mean (SD) | 139 | | | 143 (5) | 141 (4)
Median (Min, Max) | 139 | | | 143 (139, 146) | 139 (139, 146)

Note: Mean values were used when multiple lab measurements were drawn on the same participant during a measurement period (baseline, study-treatment, end/early termination or post-treatment).

Safety Population includes enrolled and dosed participants.

Table 14.3.3 Summary of Microbiology Cultures by Age/BMI Stratum Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
Total Number of Cultures | 2 | 5 | 6 | 22 | 35
Number of Participants with Cultures
N | 2 | 3 | 4 | 9 | 18
Number of Cultures per Participant
N | 4 | 3 | 4 | 11 | 22
Mean (SD) Cultures per Participant | 0.5 (0.6) | 1.7 (0.6) | 1.5 (0.6) | 2.0 (1.5) | 1.6 (1.2)
Median (Min, Max) Cultures per Participant | 0.5 (0.0, 1.0) | 2.0 (1.0, 2.0) | 1.5 (1.0, 2.0) | 2.0 (0.0, 5.0) | 1.5 (0.0, 5.0)
Cultures
Abscess Culture | 2 | 2 | 5 | 3 | 12
Blood Culture | 0 | 2 | 1 | 14 | 17
Joint Aspirate | 0 | 0 | 0 | 1 | 1
Swab Sternoclavical Joint | 0 | 0 | 0 | 1 | 1
Urine Culture | 0 | 1 | 0 | 3 | 4
Method of Acquisition
Arterial Line | 0 | 0 | 0 | 2 | 2
Aspiration | 1 | 0 | 0 | 0 | 1
Catheterization | 0 | 0 | 0 | 1 | 1
Central Line | 0 | 0 | 0 | 4 | 4
Clean Catch | 0 | 1 | 0 | 2 | 3
Cutaneous Swab | 1 | 2 | 3 | 3 | 9
Joint Aspirate | 0 | 0 | 0 | 1 | 1
Perianal | 0 | 0 | 0 | 1 | 1
Peripheral | 0 | 2 | 1 | 8 | 11
Peritoneal Fluid | 0 | 0 | 2 | 0 | 2
Culture Results
Negative | 0 | 2 | 1 | 14 | 17
Positive | 2 | 3 | 5 | 8 | 18

Note: Cultures can be positive for more than 1 organism.

Safety Population includes enrolled and dosed participants.

Table 14.3.4.1 Summary of Baseline Physical Examination Findings by Body System and Age/BMI Stratum Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
General Appearance
Normal | 3 (75.0%) | 2 (66.7%) | 3 (75.0%) | 9 (81.8%) | 17 (77.3%)
Abnormal (not clinically significant) | 1 (25.0%) | 1 (33.3%) | 1 (25.0%) | 2 (18.2%) | 5 (22.7%)
Skin
Normal | 2 (50.0%) | 0 | 3 (75.0%) | 4 (36.4%) | 9 (40.9%)
Abnormal (clinically significant) | 0 | 1 (33.3%) | 0 | 4 (36.4%) | 5 (22.7%)
Abnormal (not clinically significant) | 2 (50.0%) | 2 (66.7%) | 1 (25.0%) | 3 (27.3%) | 8 (36.4%)
Head
Normal | 2 (50.0%) | 2 (66.7%) | 3 (75.0%) | 7 (63.6%) | 14 (63.6%)
Abnormal (clinically significant) | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)
Abnormal (not clinically significant) | 1 (25.0%) | 1 (33.3%) | 1 (25.0%) | 3 (27.3%) | 6 (27.3%)
Not Examined | 1 (25.0%) | 0 | 0 | 0 | 1 (4.5%)
Cardiovascular
Normal | 3 (75.0%) | 3 (100.0%) | 4 (100.0%) | 11 (100.0%) | 21 (95.5%)
Abnormal (not clinically significant) | 1 (25.0%) | 0 | 0 | 0 | 1 (4.5%)
Respiratory
Normal | 3 (75.0%) | 3 (100.0%) | 4 (100.0%) | 10 (90.9%) | 20 (90.9%)
Abnormal (not clinically significant) | 1 (25.0%) | 0 | 0 | 1 (9.1%) | 2 (9.1%)
Abdomen
Normal | 3 (75.0%) | 2 (66.7%) | 3 (75.0%) | 9 (81.8%) | 17 (77.3%)
Abnormal (clinically significant) | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)
Abnormal (not clinically significant) | 1 (25.0%) | 1 (33.3%) | 1 (25.0%) | 1 (9.1%) | 4 (18.2%)
Nervous System
Normal | 4 (100.0%) | 3 (100.0%) | 3 (75.0%) | 7 (63.6%) | 17 (77.3%)
Abnormal (clinically significant) | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)
Abnormal (not clinically significant) | 0 | 0 | 0 | 3 (27.3%) | 3 (13.6%)
Not Examined | 0 | 0 | 1 (25.0%) | 0 | 1 (4.5%)
Musculoskeletal
Normal | 2 (50.0%) | 3 (100.0%) | 4 (100.0%) | 6 (54.5%) | 15 (68.2%)
Abnormal (clinically significant) | 1 (25.0%) | 0 | 0 | 1 (9.1%) | 2 (9.1%)
Abnormal (not clinically significant) | 1 (25.0%) | 0 | 0 | 4 (36.4%) | 5 (22.7%)
Gastro-intestinal
Abnormal (not clinically significant) | 0 | 0 | 0 | 1 (9.1%) | 1 (4.5%)

Note: The percentages are based on the total number of participants in each Age/BMI stratum or total.

Table 14.3.4.2 Summary of Post-Treatment Physical Examination Findings by Body System and Age/BMI Stratum Safety Population

| Age 2 - <12 years | | Age 12 - < 18 years | | Total; (N = 22)
| BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 3) | BMI 85th - <95th percentile; (N = 4) | BMI ≥95th percentile; (N = 11) | Total; (N = 22)
General Appearance
Normal | 4 (100.0%) | 2 (100.0%) | 4 (100.0%) | 10 (90.9%) | 20 (95.2%)
Abnormal (not clinically significant) | 0 | 0 | 0 | 1 (9.1%) | 1 (4.8%)
Skin
Normal | 2 (50.0%) | 0 | 3 (75.0%) | 4 (36.4%) | 9 (42.9%)
Abnormal (clinically significant) | 1 (25.0%) | 1 (50.0%) | 0 | 3 (27.3%) | 5 (23.8%)
Abnormal (not clinically significant) | 1 (25.0%) | 1 (50.0%) | 1 (25.0%) | 4 (36.4%) | 7 (33.3%)
Head
Normal | 3 (75.0%) | 2 (100.0%) | 3 (75.0%) | 6 (54.5%) | 14 (66.7%)
Abnormal (not clinically significant) | 1 (25.0%) | 0 | 1 (25.0%) | 3 (27.3%) | 5 (23.8%)
Not Examined | 0 | 0 | 0 | 2 (18.2%) | 2 (9.5%)
Cardiovascular
Normal | 3 (75.0%) | 2 (100.0%) | 4 (100.0%) | 11 (100.0%) | 20 (95.2%)
Abnormal (not clinically significant) | 1 (25.0%) | 0 | 0 | 0 | 1 (4.8%)
Respiratory
Normal | 4 (100.0%) | 2 (100.0%) | 4 (100.0%) | 11 (100.0%) | 21 (100.0%)
Abdomen
Normal | 4 (100.0%) | 2 (100.0%) | 4 (100.0%) | 8 (72.7%) | 18 (85.7%)
Abnormal (not clinically significant) | 0 | 0 | 0 | 2 (18.2%) | 2 (9.5%)
Not Examined | 0 | 0 | 0 | 1 (9.1%) | 1 (4.8%)
Nervous System
Normal | 4 (100.0%) | 2 (100.0%) | 4 (100.0%) | 9 (81.8%) | 19 (90.5%)
Abnormal (clinically significant) | 0 | 0 | 0 | 1 (9.1%) | 1 (4.8%)
Abnormal (not clinically significant) | 0 | 0 | 0 | 1 (9.1%) | 1 (4.8%)
Musculoskeletal
Normal | 3 (75.0%) | 2 (100.0%) | 4 (100.0%) | 5 (45.5%) | 14 (66.7%)
Abnormal (clinically significant) | 1 (25.0%) | 0 | 0 | 1 (9.1%) | 2 (9.5%)
Abnormal (not clinically significant) | 0 | 0 | 0 | 4 (36.4%) | 4 (19.0%)
Not Examined | 0 | 0 | 0 | 1 (9.1%) | 1 (4.8%)

Note: The percentages are based on the total number of participants in each Age/BMI stratum or total.

Figure 14.4.1 Clinical Outcomes over Time ID ▬

1. All doses are in mg/kg and are based on the participant’s dosing weight.

2. Green filled circles represent the standard of care doses.

3. Red filled triangles are fresh timed plasma samples and red open triangles are scavanged samples.

4. Fresh and scavanged plasma PK concentrations (mg/L) for Clindamycin are shown with red stars.

Figure 14.4.2.1 Summary of Clinical Laboratory Hematology Measurement Hematocrit (%) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.2.2 Summary of Clinical Laboratory Hematology Measurement Hemoglobin (g/dL) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.2.3 Summary of Clinical Laboratory Hematology Measurement Platelet Count (10^3^/µL) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.2.4 Summary of Clinical Laboratory Hematology Measurement White Blood Count (10^3^/µL) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.1 Summary of Clinical Laboratory Chemistry Measurement Albumin (g/dL) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.2 Summary of Clinical Laboratory Chemistry Measurement Alanine Aminotransferase ALT (U/L) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.3 Summary of Clinical Laboratory Chemistry Measurement Aspartate Aminotransferase AST (U/L) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.4 Summary of Clinical Laboratory Chemistry Measurement Bicarbonate (mEq/L) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.5 Summary of Clinical Laboratory Chemistry Measurement Total Bilirubin (mg/dL) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.6 Summary of Clinical Laboratory Chemistry Measurement Blood Urea Nitrogen BUN (mg/dL) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.7 Summary of Clinical Laboratory Chemistry Measurement Calcium (mg/dL) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.8 Summary of Clinical Laboratory Chemistry Measurement Chloride (mEq/L) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.9 Summary of Clinical Laboratory Chemistry Measurement Creatinine (mg/dL) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.10 Summary of Clinical Laboratory Chemistry Measurement Glucose (mg/dL) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.11 Summary of Clinical Laboratory Chemistry Measurement Potassium (mEq/L) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.12 Summary of Clinical Laboratory Chemistry Measurement Total Protein (g/dL) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

Figure 14.4.3.13 Summary of Clinical Laboratory Chemistry Measurement Sodium (mEq/L) Safety Population

Note: Box represents the 25^th^ and 75^th^ percentiles, whiskers the 5^th^ and 95^th^ percentiles and stars represent outliers. The horizontal line is the median and the triangle is the mean value. The change value is the end of study dose value minus the baseline (pre-study dose) value.

SAE Narratives have been redacted to protect participant privacy