# 5 ETHICS

## 5.1 Institutional Review Board (IRB)

All investigators ensured that the protocol and consent form were reviewed and approved by the appropriate Institutional Review Boards/Independent Ethics Committees (IRB/IEC) prior to the start of any study procedures. The IRB/IEC were appropriately constituted and performed their functions in accordance with FDA regulations, ICH GCP guidelines, and local requirements as applicable. IRBs approved: all protocol amendments (except for logistical or administrative changes); written informed consent documents and document updates; participant recruitment procedures; written information to be provided to the participants; available safety information; information about payment and compensation available to participants; the investigator’s curriculum vitae and or other evidence of qualifications; and any other documents requested by the IRB/IEC and regulatory authority as applicable. Detailed IRB information is provided in Appendix 16.1.3.

## 5.2 Ethical Conduct of the Study

This study was conducted in accordance with the ethical principles originating from the Declaration of Helsinki and current GCP, and in compliance with federal, state and local regulatory requirements, including 21 CFR 312, 21 CFR 50 and 21 CFR 56.

## 5.3 Participant Information, Consent, and Assent

All participants in the NICHD-2012-CLN01 study were minors (under the age of 18 years). The investigator or designated representative explained the nature of the study to the participant and the participant’s parents or legal guardian, to the extent compatible with the participant’s understanding, and answered all questions regarding this study. Prior to any study-related screening procedures being performed on the participant, the informed consent (parental permission) statement was signed and dated by the participant’s parent or legal guardian and by the person who administered the informed consent. The participant gave assent when appropriate. A copy of the signed informed consent form (ICF) was given to the participant, or the participant’s parents or legal guardian, and the original was placed in the participant’s medical record. An entry was also made in the participant’s source documents to confirm that informed consent was obtained prior to any study-related procedures and that the participant, or the participant’s parents or legal guardian, received a signed copy. In addition, the Health Insurance Portability and Accountability Act (HIPAA) statement was reviewed, signed, and dated by the participant’s parent or legal guardian as a part of the ICF or as a separate form. A sample ICF is provided in Appendix 16.1.3.