# 16 APPENDICES (list of contents)

16.1 Study Information - NICHD-2012-CLN01
  16.1.1 Protocol and Protocol Amendments
  16.1.2 Sample Case Report Form
  16.1.3 Institutional Review Boards (IRBs) and Consent/Assent Information
  16.1.4 Description of Investigators
  16.1.5 Signature Pages
  16.1.6 Listing of Lot Numbers by Participant
  16.1.7 Randomization Scheme
  16.1.8 Audit Certificates
  16.1.9 Statistical Analysis Plan
  16.1.10 Documentation of Inter-Laboratory Standardization Methods and Quality Assurance Procedures
  16.1.11 Publications Based on the Study
  16.1.12 Important Publications Referenced in the Report
16.2 Participant Data Listings - CLN01
16.3 Case Report Forms for Participant with SAE - CLN01
16.4 Miscellaneous
  16.4.1 NICHD-2011-POP01 Protocol and Protocol Amendments
  16.4.2 NICHD-2012-STA01 Protocol and Protocol Amendments
    16.4.3.1 PK Report (Narrative, Tables, and Figures)
    16.4.3.2 PK Datasets
    16.4.3.3 PK Report Data Dictionary (PK-define.pdf)
    16.4.3.4 PK Control Streams and Output
  16.4.4 Clindamycin Assay Validation Report
  16.4.5 NICHD-2012-CLN01 Interim Analysis Report
16.5 Datasets and Define.pdf - CLN01
  16.5.1 NICHD-2012-CLN01 Datasets
  16.5.2 NICHD-2012-CLN01 Data Dictionary (CLN01-define.pdf)

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/228258