# 4 Glossary of Abbreviations and Terms

Abbreviation: Definition
AE: Adverse Event
ASD: Atrial Septal Defect
AST: Aspartate Transaminase
ALT: Alanine Transaminase
AOP: Apnea of Prematurity
AST: Aspartate Transaminase
BPCA: Best Pharmaceuticals for Children Act
BPD: Bronchopulmonary Dysplasia
CAP: Caffeine for Apnea of Prematurity (Trial)
CEI: Clinical Event of Interest
CFR: Code of Federal Regulations
CNS: Central Nervous System
DCC: Data Coordinating Center
DCRI: Duke Clinical Research Institute
EHR: Electronic Health Record
FDA: Food and Drug Administration
GA: Gestational Age
GCP: Good Clinical Practice
HIPAA: Health Insurance Portability and Accountability Act
ICH: International Council for Harmonisation
IND: Investigational New Drug Application
IRB: Institutional Review Board
IVH: Intraventricular Hemorrhage
kg: Kilogram
LEI: Laboratory Event of Interest
mg: Milligram
N: Number (typically refers to patients)
NICHD: National Institute of Child Health and Human Development
NDI: Neurodevelopmental impairment
NEC: Necrotizing Enterocolitis
NICU: Neonatal Intensive Care Unit
NIH: National Institutes of Health
OR: Odds Ratio
PDA: Patent Ductus Arteriosus
PI: Principal Investigator
PK: Pharmacokinetics
PMA: Postmenstrual Age
PNA: Postnatal Age
PROP: Prematurity and Respiratory Outcomes Program
PTN: Pediatric Trials Network
ROP: Retinopathy of Prematurity
SOC: Standard of Care
VSD: Ventricular Septal Defect
WHO: World Health Organization