# 2 Synopsis

IND SPONSOR and PRINCIPAL INVESTIGATOR: P. Brian Smith, MD, MPH, MHS, Professor of Pediatrics, Duke University Medical Center, Duke Clinical Research Institute.

FUNDING SPONSOR: The Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD)

NAME OF STUDY DRUG: Caffeine Citrate

TITLE OF STUDY: Safety and Efficacy of Caffeine Citrate in Premature Infants

PROTOCOL ID: NICHD-2014-CAF01

IND: PIND 125,696

PUBLICATIONS: Abstract presented at Pediatric Academic Societies (PAS) meeting, May 6-9, 2017: Dumitrescu MP, Smith PB, Zhao J et al. Safety of off-label use of caffeine citrate in premature infants.

STUDY PERIOD: | PHASE OF DEVELOPMENT:
(Date of First Participant Visit): Not applicable; (Date of Last Participant Visit): Not applicable | Data Analysis

PRIMARY OBJECTIVES:

1. To characterize safety of caffeine citrate.
2. To characterize efficacy of caffeine citrate.
3. To evaluate the caffeine citrate exposure-response relationship.

METHODOLOGY:

The study included the retrospective analysis of clinical data for premature infants who received caffeine citrate per standard of care (SOC), gathered from three sources:

- Pediatrix Medical Group (Pediatrix) electronic medical records;
- Electronic Health Records (EHR) from four sites in the Pediatric Trials Network (PTN); and
- The National Heart Lung & Blood Institute (NHLBI) Prematurity and Respiratory Outcome Program (PROP) study.

In addition, the study included a review of published data from the randomized, controlled Caffeine for Apnea of Prematurity (CAP) trial.

NUMBER OF PARTICIPANTS (PLANNED AND ANALYZED):

[underlined: Pediatrix]

- Planned: 75,000
- Analyzed: 86,647

[underlined: EHR]

- Planned: 400
- Analyzed: 410

[underlined: PROP]

- Planned: 750
- Analyzed: 794

[underlined: CAP]

- Published data from 2006 infants

INCLUSION AND EXCLUSION CRITERIA:

[underlined: Pediatrix]

Inclusion criteria:

1. Discharged from an intensive care nursery managed by the Pediatrix Medical Group from 2005 to 2013
2. <33 weeks gestational age at birth
3. ≥1 day of caffeine therapy
4. <120 days of age (PNA) at earliest dose of caffeine

Exclusion criteria:

1. Known major congenital anomaly

[underlined: EHR]

Inclusion criteria:

1. <28 weeks gestational age at birth
2. <120 days of age (PNA) at earliest dose of caffeine
3. ≥1 day of caffeine therapy
4. Admitted to an intensive care nursery from 2005 to 2013

Exclusion criteria:

1. Known major congenital anomaly

[underlined: PROP]

Inclusion Criteria:

1) Enrolled in PROP
2) ≥ 1 day of caffeine citrate therapy
3) < 120 days of age (PNA) at earliest dose of caffeine citrate

Exclusion Criteria:

1. None.

[underlined: CAP]:

Inclusion criteria:

1. 500-1250 g birth weight
2. First 10 days of life
3. Considered by clinician as candidate for methylxanthine therapy

Exclusion criteria:

1. Dysmorphic feature or congenital anomaly likely to affect neurologic outcome or life expectancy.
2. Unlikely to be available for long-term follow-up
3. Previously treated with methylxanthines

TEST PRODUCT, DOSE AND MODE OF ADMINISTRATION, BATCH NUMBER:

Not applicable.

REFERENCE THERAPY, DOSE AND MODE OF ADMINISTRATION, BATCH NUMBER:

Not applicable.

CRITERIA FOR EVALUATION:

[underlined: Pediatrix, EHR, and PROP Data]

For the Pediatrix, EHR, and PROP data, clinical events of interest (CEI) and laboratory events of interest (LEI) were defined prior to medical chart review (EHR) and data analysis (Pediatrix and PROP). CEIs included bronchopulmonary dysplasia (BPD); medical and surgical necrotizing enterocolitis (NEC); spontaneous intestinal perforation; Grade II-IV intraventricular hemorrhage (IVH); seizure; arrhythmia; patent ductus arteriosus (PDA); and death. LEIs included laboratory values indicating mild or severe events associated with serum electrolytes (hyperglycemia; hypoglycemia; hypernatremia; hyponatremia; hypercalcemia; hypocalcemia); renal dysfunction (elevated creatinine); and liver dysfunction (elevated AST and elevated ALT).

[underlined: CAP Study Publications]

For the CAP trial, published data on subject demographics, clinical characteristics, and caffeine citrate administration were reviewed, and published data related to mortality, BPD, and NEC were analyzed.

STATISTICAL METHODS:

For Pediatrix and EHR analyses, descriptive analysis was used to examine the frequency of clinical events and laboratory events. Frequency of events was analyzed at both the participant level (clinical events) and the participant-day level (laboratory events). The number and percentage of participants who experienced an event and the total number of events were summarized. Analyses in this study are exploratory or descriptive in nature.

For PROP analysis, the frequency of clinical events is summarized descriptively at participant level. The number and percentage of participants who experienced an event and the total number of events are summarized. For EHR analysis, clinical characteristics are summarized by whether the participant had an event. For EHR and PROP analysis, participant-level descriptive summaries of sex, race/ethnicity, and key endpoints are presented.

RESULTS:

Efficacy:

Pediatrix: A total of 17,769 (20.5%) infants exposed to caffeine citrate developed BPD.

EHR: A total of 119 (36.6%) infants developed BPD. A 1 day increase of the caffeine use was associated with a 4% decrease in the odds of BPD (odds ratio [OR]=0.96, P<0.01).

CAP: Infants who received caffeine had significantly lower rates of BPD compared to infants that received placebo (36.3% vs. 46.9%, OR=0.63, P<0.001).

Safety:

Pediatrix: A total of 3357 (3.9%) infants died on the day of caffeine citrate exposure; 3426 (4.0%) developed medical NEC; 1407 (1.6%) developed surgical NEC; 1227 (1.4%) developed spontaneous intestinal perforation; 4318 (5.0%) developed grade II IVH; 4975 (5.7%) developed grade III IVH; 2677 (3.1%) developed PDA requiring surgical closure; 1023 (1.2%) developed seizures; and 357 (0.4%) infants developed arrhythmias.

EHR: A total of 9 (2.2%) infants died on the day of caffeine citrate exposure; 19 (4.6%) developed medical NEC; 18 (4.4%) developed surgical NEC; 19 (4.6%) developed spontaneous intestinal perforation; 29 (7.1%) developed grade II IVH; 52 (12.7%) developed grade III IVH; 214 (52.2%) developed medical PDA, while 50 (12.2%) developed PDA requiring surgical closure; 226 (55.1%) developed PDA requiring either medical or surgical treatment; 13 (3.2%) developed seizures; and no infants developed arrhythmias. Multivariable analysis of factors predictive of NEC identified increasing dose (OR=0.78, P < 0.01) and duration (OR=0.93, P < 0.0001) of caffeine treatment with a reduction in the odds of development of NEC

PROP: A total of 18 (2.3%) infants died on the day of caffeine citrate exposure; 48 (6.0%) developed medical NEC; 17 (2.1%) developed surgical NEC; 15 (1.9%) developed spontaneous intestinal perforation; 48 (6.0%) developed grade II IVH; 80 (10.1%) developed grade III or IV IVH. Medical PDA occurred in 397 (50.0%) infants, with 28 (3.5%) requiring surgery for PDA on a day of caffeine citrate exposure; 300 (37.8%) had BPD at 36 weeks PMA; and 161 (20.3%) experienced a sepsis event with a positive blood culture during hospital stay.

CAP: Significant findings among infants in the caffeine citrate group compared to the placebo group include a reduced frequency of medical treatment for PDA (29% vs. 38%, P<0.001), and reduced frequency of surgical closure of PDA (4.5% vs. 13%), P<0.001). The incidence of death before hospital discharge, brain injury detected by ultrasound, and NEC did not differ between the two groups. At the 18-21-month follow up, caffeine citrate was associated with a significant reduction the incidence of cerebral palsy (4.4% vs. 7.3%, P=0.009) and cognitive delay (34% vs. 38%, P=0.04). At the 5-year follow up, the incidence of death or survival with at least 1 impairment did not differ between the caffeine citrate and placebo groups (21% vs. 25%, P=0.09).

CONCLUSIONS: Caffeine citrate used at greater doses for longer durations in more immature (e.g., lower GA) infants than the FDA label appears to be a safe therapy for the treatment of AOP. Caffeine citrate use is not associated with an increased risk for NEC.

DATE OF THE DRAFT CSR: March 14, 2018