# 13 Discussion and Overall Conclusions

## 13.1 Discussion

The NICHD-2014-CAF01 study addressed the significant gaps between the caffeine citrate label and contemporary clinical practice. Although caffeine citrate is labeled for the short-term treatment of AOP in infants between 28 and <33 weeks gestational age, the NICHD-2014-CAF01 study included a large number of infants born <28 weeks gestation, with 410 infants in the EHR dataset; 28,924 infants in the Pediatrix dataset; and 794 infants in the PROP dataset. Reflecting current clinical practice [7, 8], the durations and doses of caffeine citrate administered in all three datasets greatly exceeded label-recommended durations and doses. In the EHR study, infants were exposed to a median daily dose of 8 mg/kg/day (range 4 to 25) with a median duration of 60 days (range 1 to 144). In the Pediatrix study, infants were exposed to a median daily dose of 7 mg/kg/day (interquartile range, IQR: 5.2 to 9.3) and duration of 29 days (IQR: 16 to 45). In the PROP study, infants were exposed to a median daily dose of 8 mg/kg/day (range 3 to 40) with a median duration of 47 days (range 1 to 116).

Caffeine citrate appears to be safe during short-term and long-term follow up. In the CAP trial (mean GA of 27 weeks, with a standard deviation ± 2), the rates of death before hospital discharge, brain injury diagnosed by ultrasound, and NEC was not different between infants treated with caffeine citrate versus placebo. Mortality also did not differ between caffeine-treated and placebo-treated infants during follow up at 18 to 21 months and at 5 years of age. Survival with neurological impairment also did not differ between the caffeine citrate and placebo groups at the 5-year follow up.

Similar to the CAP results and other evidence in the literature [9], the NICHD-2014-CAF01 study suggests that caffeine citrate is not associated with an increased risk for NEC. In the Pediatrix data, medical and surgical NEC were infrequent outcomes. The CAP study failed to find a significant difference in rates of NEC between the caffeine citrate and placebo groups [10]. Dose response modeling results using the EHR dataset showed an inverse relationship between mean study dose and duration of therapy with development of NEC, with higher doses and longer durations associated with a decrease in risk of NEC.

Death or brain injury were infrequent outcomes in the EHR and Pediatrix studies, and the CAP trial showed no significant difference in mortality or brain injuries between the treatment and placebo groups. The CAP trial showed a protective effect of caffeine citrate therapy against PDA requiring therapeutic closure. Dose response modeling results using simulated plasma caffeine concentrations in the EHR study showed that higher maximal plasma caffeine concentrations were associated with increased risk in development of PDA requiring therapeutic closure. This finding may be due to the empiric use of higher caffeine doses to treat worsening apnea initially presumed to be due to apnea of prematurity prior to the ordering of tests used to confirm a PDA diagnosis [18].

The CAP Trial provides evidence that use of caffeine citrate for AOP may reduce the incidence of BPD among extremely premature infants. Data from the retrospective studies involving the Pediatrix, EHR, and PROP databases show that the incidence of BPD among extremely premature infants treated with caffeine citrate is comparable to the incidence of BPD seen in infants treated with caffeine citrate in the CAP Trial. The EHR dataset provides supporting evidence that longer durations of caffeine citrate use is associated with decreased odds in the development of BPD.

## 13.2 Conclusions

Caffeine citrate used at greater doses for longer durations in more immature (e.g. lower GA) infants than what is recommended in the current drug label appears to be a safe therapy for the treatment of AOP. Caffeine citrate use is not associated with an increased risk for NEC.