# 12 Safety Evaluation

For the Pediatrix, EHR, and PROP data, safety was assessed retrospectively, according to identified CEIs.

## 12.1 Retrospective Analyses

### 12.1.1 Pediatrix and PROP Safety Analyses

Separate reports have been prepared for the Pediatrix data (16.4.1.1) and the PROP data (16.4.2.1).

### 12.1.2 EHR

#### 12.1.2.1 Clinical Events of Interest

##### 12.1.2.1.1 Death

Table 12-1 summarizes deaths by site while infants were on caffeine citrate. A total of 9 (1.9%) infants died on a day of caffeine citrate exposure prior to discharge or transfer from hospital. ▬ reported the highest death incidence of 4 (3.7%); 2 (1.9%) died at ▬; 3 (3.2%) died at ▬; and no deaths were reported at ▬. Six (3.2%) of the female infants and 3 (1.3%) of the male infants died. The median duration of therapy for the surviving and deceased infants while on caffeine citrate were 60 days and 9 days, respectively. The median GA for the surviving and deceased infants while on caffeine citrate was 26 weeks and 24 weeks, respectively. The median birth weight for the surviving and deceased infants while on caffeine citrate was 810 grams and 595 grams, respectively. The median cumulative doses for the surviving and deceased infants while on caffeine citrate was 459 mg/kg and 52 mg/kg, respectively. The median maximum daily dose for the surviving and deceased infants was 20 mg/kg/day and 19 mg/kg/day. The median maximum plasma concentration for the surviving and deceased infants was 25 mg/L and 14 mg/L. Plasma concentrations were reported for 3 deceased infants within 7 days of death; all values were below 31 mg/L. There were 19 infants who died after initiation of caffeine citrate therapy who were not receiving caffeine citrate on day of their death (Table 14.2.1.1.2.1). Of these 19 deaths, 18 were reported within 3 days of the last caffeine citrate dose.

Table 12-1 Deaths on the Day of Caffeine Citrate Exposure by Site

| ▬; (N=100) | ▬; (N=108) | ▬; (N=107) | ▬; (N=95) | Total; (N=410)
Number of Deaths | 0 | 2 (1.9%) | 4 (3.7%) | 3 (3.2%) | 9 (2.2%)

Source: Table 14.2.1.1.1.1

##### 12.1.2.1.2 Other Clinical Events of Interest Attributed to Caffeine Citrate Exposure

An overall summary of clinical events of interest attributed to caffeine citrate exposure by site is presented in Tables 12-2, 12-3, 14.2.1.1.1.1, 14.2.1.1.1.2, and 14.2.1.2.1 - 14.2.1.2.8. There were no infants with reported arrhythmia events.

Per study PI decision, all BPD and IVH events (Grade II, III, or IV) are included in this analysis regardless of whether the infant was receiving caffeine citrate on the day of the event. In the BPD analyses, all infants discharged from hospital before 36 weeks of PMA were excluded.

Infants from ▬ reported the highest incidence of BPD (46/94, 49%); PDA requiring medical treatment (69/100, 69.0%) and PDA requiring either medical or surgical treatment (74/100, 74.0%). ▬ reported the highest incidence of medical NEC (9/108, 8.3%); spontaneous intestinal perforation (7/108, 6.5%); PDA requiring surgical treatment (21/108, 19.4%); and seizure (9/108, 8.3%). ▬ had the highest incidence of surgical NEC (8/107, 7.5%) and intraventricular hemorrhage (Grade II: 8/107, 7.5%; and Grade III or IV: 15/107, 14.0%). The median maximum daily dose (mg/kg/day) for infants with seizure events was slightly higher than the median maximum daily dose for infants without seizure events (22 mg/kg/day vs 20 mg/kg/day).

Table 12-2 CEIs Attributed to Caffeine Citrate Exposure by Site

| ▬; (N=100) | ▬; (N=108) | ▬; (N=107) | ▬; (N=95) | Total; (N=410)
BPD
Number of Participants at Risk of BPD^*^ | 94 | 85 | 73 | 73 | 325
Number of Participants with BPD | 46 (48.9%) | 23 (27.1%) | 21 (28.8%) | 29 (39.7%) | 119 (36.6%)
Medical NEC
Number of Events | 1 | 9 | 4 | 5 | 19
Number of Participants | 1 (1.0%) | 9 (8.3%) | 4 (3.7%) | 5 (5.3%) | 19 (4.6%)
Surgical NEC
Number of Events | 4 | 3 | 8 | 3 | 18
Number of Participants | 4 (4.0%) | 3 (2.8%) | 8 (7.5%) | 3 (3.2%) | 18 (4.4%)
Spontaneous Intestinal Perforation
Number of Events | 5 | 7 | 5 | 2 | 19
Number of Participants | 5 (5.0%) | 7 (6.5%) | 5 (4.7%) | 2 (2.1%) | 19 (4.6%)
Grade II Intraventricular Hemorrhage
Number of Events | 7 | 7 | 8 | 7 | 29
Number of Participants | 7 (7.0%) | 7 (6.5%) | 8 (7.5%) | 7 (7.4%) | 29 (7.1%)
Grade III or IV Intraventricular Hemorrhage
Number of Events | 17 | 10 | 15 | 10 | 52
Number of Participants | 17 (17.0%) | 10 (9.3%) | 15 (14.0%) | 10 (10.5%) | 52 (12.7%)
PDA Requiring Surgical Treatment
Number of Events | 14 | 21 | 9 | 6 | 50
Number of Participants | 14 (14.0%) | 21 (19.4%) | 9 (8.4%) | 6 (6.3%) | 50 (12.2%)
PDA Requiring Medical Treatment^**^
Number of Events | 69 | 61 | 48 | 36 | 214
Number of Participants | 69 (69.0%) | 61 (56.6%) | 48 (44.9%) | 36 (37.9%) | 214 (52.2%)
PDA Requiring Either Medical or Surgical Treatment
Number of Events | 74 | 67 | 48 | 37 | 226
Number of Participants | 74 (74.0%) | 67 (62.0%) | 48 (44.9%) | 37 (38.9%) | 226 (55.1%)
Seizure
Number of Events | 2 | 9 | 2 | 0 | 13
Number of Participants | 2 (2.0%) | 9 (8.3%) | 2 (1.9%) | 0 | 13 (3.2%)

Source: Table 14.2.1.1.1.1

* Per NICHD BPD definition, participants discharged or transferred from hospital before 36 weeks of PMA are excluded from this analysis. See Section 9.6.4.1 for definition of BPD used for the EHR data..

** Participants who used ibuprofen or indomethacin as concomitant medication are considered to have PDA requiring medical treatment.

There were 119 diagnoses of severe respiratory AEs (BPD) reported in 119 (36.6%) infants.

There were 19 diagnoses of mild gastrointestinal events (Medical NEC) reported in 19 (4.6%) infants, and 37 diagnoses of severe gastrointestinal events (Surgical NEC and spontaneous intestinal perforation) in 35 (8.5%) infants.

There were 29 mild neurologic events (Grade II IVH) reported in 29 (7.1%) infants, and 65 severe neurological events (Grade III or IV IVH, seizure) reported in 57 (13.9%) infants.

There were 50 severe diagnosis cardiovascular events (PDA requiring surgical treatment) in 50 infants (12%).

Table 12-3 CEIs Attributed to Caffeine Citrate Exposure by Body System and Site

| ▬; (N=100) | | ▬; (N=108) | | ▬; (N=107) | | ▬; (N=95) | | Total; (N=410)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Respiratory
Number of Participants at Risk of BPD* | N/A | 94 | N/A | 85 | N/A | 73 | N/A | 73 | N/A | 325
Number of Participants with BPD | N/A | 46 (48.9%) | N/A | 23 (27.1%) | N/A | 21 (28.8%) | N/A | 29 (39.7%) | N/A | 119 (36.6%)
Gastrointestinal
Number of Events | 1 | 9 | 9 | 10 | 4 | 13 | 5 | 5 | 19 | 37
Number of Participants | 1 (1.0%) | 8 (8.0%) | 9 (8.3%) | 10 (9.3%) | 4 (3.7%) | 13 (12.1%) | 5 (5.3%) | 4 (4.2%) | 19 (4.6%) | 35 (8.5%)
Neurologic
Number of Events | 7 | 19 | 7 | 19 | 8 | 17 | 7 | 10 | 29 | 65
Number of Participants | 7 (7.0%) | 17 (17.0%) | 7 (6.5%) | 15 (13.9%) | 8 (7.5%) | 15 (14.0%) | 7 (7.4%) | 10 (10.5%) | 29 (7.1%) | 57 (13.9%)
Cardiovascular
Number of Events | N/A | 14 | N/A | 21 | N/A | 9 | N/A | 6 | N/A | 50
Number of Participants | N/A | 14 (14.0%) | N/A | 21 (19.4%) | N/A | 9 (8.4%) | N/A | 6 (6.3%) | N/A | 50 (12.2%)
General
Number of Events | N/A | 0 | N/A | 2 | N/A | 4 | N/A | 3 | N/A | 9
Number of Participants | N/A | 0 | N/A | 2 (1.9%) | N/A | 4 (3.7%) | N/A | 3 (3.2%) | N/A | 9 (2.2%)

Source: Table 14.2.1.1.1.2

An overall summary of all clinical events diagnosed after initiation of caffeine citrate therapy by site is presented in Tables 14.2.1.1.2.1 and 14.2.1.1.2.2.

#### 12.1.2.2 Laboratory Events of Interest

Summaries of LEIs attributed to caffeine citrate exposure (number of events, events per day per participant and number of infants) by severity, by GA or PNA group, and by site are presented in Tables 12-4, 14.2.2.1.1, 14.2.2.1.2, 14.2.2.2.1 to 14.2.2.2.7.

The highest rates of mild LEIs occurred in infants at ▬ (97/107, 90.7%) and ▬ (86/95, 90.5%). ▬ reported the highest rate of mild LEIs related to renal dysfunction (17/108, 15.7%). Overall, the median maximum doses for infants without events were higher or equal to the median of maximum dose prior to events for the infants with events for all LEIs.

A total of 3926 mild LEIs related to serum electrolytes were reported in 352 (85.9%) infants: hyperglycemia in 301 (73.4%); hypoglycemia in 110 (26.8%); hypernatremia in 96 (23.4%); hyponatremia in 52 (12.7%); hypercalcemia in 6 (1.5%); and hypocalcemia in 74 (18.0%) infants. A total of 74 severe LEIs (related to serum electrolytes were reported in 44 (10.7%) infants: hyperglycemia 11 (2.7%); hypoglycemia in 19 (4.6%); hypernatremia 4 (1.0%); hyponatremia in 3 (0.7%); and hypocalcemia in 12 (2.9%) infants.

A total of 83 mild LEIs related to renal dysfunction were reported in 28 (6.8%) infants; all were from infants with elevated creatinine. There were 13 severe LEIs related to renal dysfunction reported in 1 infant.

There were 3 mild LEIs related to liver dysfunction reported in 2 (0.5%) infants: elevated ALT in one infant and elevated AST in the other.

Table 12-4 Laboratory Events of Interest Attributed to Caffeine Citrate Exposure by Laboratory Test, Site and Severity

| ▬; (N=100) | | ▬; (N=108) | | ▬; (N=107) | | ▬; (N=95) | | Total; (N=410)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Serum Electrolytes
Number of Events | 674 | 16 | 514 | 17 | 1266 | 23 | 1472 | 18 | 3926 | 74
Number of Participants | 86 (86.0%) | 14 (14.0%) | 83 (76.9%) | 11 (10.2%) | 97 (90.7%) | 10 (9.3%) | 86 (90.5%) | 9 (9.5%) | 352 (85.9%) | 44 (10.7%)
Renal Dysfunction
Number of Events | 5 | 13 | 57 | 0 | 15 | 0 | 6 | 0 | 83 | 13
Number of Participants | 3 (3.0%) | 1 (1.0%) | 17 (15.7%) | 0 | 6 (5.6%) | 0 | 2 (2.1%) | 0 | 28 (6.8%) | 1 (0.2%)
Liver Dysfunction
Number of Events | 0 | 0 | 2 | 0 | 0 | 0 | 1 | 0 | 3 | 0
Number of Participants | 0 | 0 | 1 (0.9%) | 0 | 0 | 0 | 1 (1.1%) | 0 | 2 (0.5%) | 0

Source: Table 14.2.2.1.2

#### 12.1.2.3 Concomitant Medications

Concomitant medications used during the study were not coded according to the WHO (World Health Organization) drug classification system due to different indications in neonates. Specifically, indomethacin was classified as a cardiovascular, rather than musculoskeletal, drug. Table 14.3.2 and Table 12-5 list the most frequently used (≥10% of the infants) concomitant medications.

Table 12-5 Listing of Concomitant Medications

Suggested Drug Classification Medication Name | Infants With Medication N (%)
ANTI-INFECTIVES FOR SYSTEMIC USE
Erythromycin | 130 (31.7%)
Fluconazole | 77 (18.8%)
CARDIOVASCULAR SYSTEM
Furosemide | 246 (60%)
Indomethacin | 196 (47.8%)
Dopamine | 113 (27.6%)
Phenylephrine | 86 (21%)
Chlorothiazide | 55 (13.4%)
NERVOUS SYSTEM
Fentanyl | 189 (46.1%)
Acetaminophen | 150 (36.6%)
Morphine | 106 (25.9%)
Midazolam | 105 (25.6%)
Lorazepam | 81 (19.8%)
Lidocaine | 49 (12%)
SYSTEMIC HORMONAL PREPARATIONS, EXCLUDING SEX HORMONES AND INSULIN
Hydrocortisone | 87 (21.2%)

Source: Table 14.3.2

#### 12.1.2.4 Dose Response Modeling Results for Selected CEIs Attributed to Caffeine Citrate Exposure

Dose response analyses and modeling results for selected CEIs and caffeine citrate exposure (BPD, NEC, and medical PDA or PDA requiring surgical treatment) are presented in Tables 12-6, 14.2.1.2.2, 14.2.1.2.3, 14.2.1.2.7, and 14.2.1.3.1-3. CEIs and caffeine citrate exposure were evaluated through logistic regression models by whether the event occurred or did not occur on a day of caffeine citrate dosing, or whether or not BPD occurred during treatment in the evaluable population. The key factors in the model are site, gestational age, birth weight (by units of 100 grams), mean study dose, duration of therapy (day) and concomitant medications. The maximum plasma concentration (for BPD) and most current plasma concentration (for NEC and PDA) have been investigated in separate models. All tests are based on α=0.05.

Among 325 infants at risk, 119 (37%) developed BPD. Infants who died, were discharged or transferred from hospital before 36 weeks of PMA were excluded from this analysis. The logistic regression model did not show a significant association between mean study dose and BPD (p-value=0.33). The duration of treatment was significant with a p-value of <0.01. Infants with longer duration of therapy had lower risk of developing BPD, with the odds of experiencing BPD being reduced by 4% (OR=0.96) with every additional day on caffeine citrate. The relationship between BPD and the maximum plasma concentration was also investigated in the subset of participants with one or more recorded plasma concentrations. After adjusting for other covariates in the model, maximum plasma concentration was not associated with risk of BPD (OR=0.96, P=0.23).

There were 37 NEC events (either medical or surgical NEC events) in 35 (9%) participants. The significant factors from the logistic regression model included mean study dose with p-value of <0.01 (OR=0.78,) and duration of therapy with p-value of <0.0001 (OR=0.93). The most current plasma concentration (OR=1.1, p-value=0.07) is borderline significant in the subset model. Site was excluded from the plasma model as a covariate due to sample size constraints.

A total of 226 (55%) infants had either medical PDA or PDA requiring surgical treatment. In the logistic regression model, both mean study dose (p-value=0.01; OR=0.87) and duration of therapy (p-value<0.0001; OR=0.85) were statistically significant. Current plasma concentration is borderline significant (OR=1.39, p-value=0.07) in the subset model. Site, cardiovascular and systemic hormonal concomitant medications were excluded from the plasma model as covariates due to sample size constraints.

Table 12-6 Dose Response Modeling Results for Selected CEIs and Caffeine Citrate Exposure

| BPD (N=119) | | NEC (N=35) | | PDA (N=226)
Key Factors (All participants) | Odds Ratio | P-value | Odds Ratio | P-value | Odds Ratio | P-value
Mean Study Dose^1^ (mg/kg/day) | 0.91 | 0.33 | 0.78 | <0.01 | 0.87 | 0.01
Duration of Therapy^2^ (day) | 0.96 | <0.01 | 0.93 | <0.0001 | 0.85 | <0.0001
| BPD (N=47) | | NEC (N=13) | | PDA (N=48)
Key Factors (Participants with reported plasma concentrations) | Odds Ratio | P-value | Odds Ratio | P-value | Odds Ratio | P-value
Maximum Plasma Concentration (mg/L)^3^ | 0.96 | 0.23 | N/A | N/A | N/A | N/A
Most Current Plasma Concentration^4^ (mg/L) | N/A | N/A | 1.10 | 0.07 | 1.39 | 0.07
Duration of Therapy^2^ (day) | 0.94 | 0.02 | 0.94 | <0.01 | 0.78 | <0.01

1 Mean study dose-Participants With Event: Cumulative dose/dose days until the event day. Participants Without Event: Cumulative dose/dose days during the study period.

2 Duration of caffeine therapy-Participant with Event: Dose days until the event day. Participants without Event: Dose days during the study period.

3 3Maximum Plasma Concentration-Participants With Event: the maximum plasma concentration prior to the event. Participants Without Event: the maximum plasma concentration reported during the study period. The BPD subset model includes only participants with the reported plasma concentration variable.

4 Most Current Plasma Concentration-Participants With Event: the measure of plasma concentration recorded closest to the time of the event (within 7 days). Participants Without Event: the last plasma concentration reported during the study period. The NEC and PDA models include only participants with the reported plasma concentration variable.

Source: Tables 14.2.1.3.1.1 and 2 (BPD), Tables 14.2.1.3.2.1 and 2 (NEC) and Tables 14.2.1.3.3.1 and 2 (PDA)

There were 2 major limitations in the analysis of relationships between plasma concentrations and the selected CEIs. First, only 108/380 (28.4%) infants who developed a CEI had concentration data available for analysis. Second, standard of care caffeine level measurements were typically random samples and might not reflect the maximal concentrations exposed to the infant. To overcome these limitations, plasma caffeine concentrations were predicted by performing Monte Carlo simulations using an existing population PK model of caffeine after intravenous or oral administration to preterm infants with apnea of prematurity [17]. Maximal caffeine concentrations were simulated for each infant, and this data was modeled as a predictor of BPD, NEC, or PDA events, respectively, via logistic regression for the full safety population (Tables 14.2.1.3.1.3 (BPD), 14.2.1.3.2.3 (NEC), and 14.2.1.3.3.3 (PDA). Detailed methods for simulating plasma concentration in the safety population are summarized in a statement of methodology included in Appendix 16.5.2. These models were similarly adjusted for demographic and clinical covariates as above.

The parameter estimates for plasma concentration were comparable between the simulated and actual value models (Table 12.7). Similar to the actual value model, there were no significant relationships in the simulated value model between maximal plasma caffeine concentrations and development of BPD or NEC. The estimate for the most current plasma concentration in the PDA model, which was borderline significant in the actual subset model, was reduced and statistically significant in the model containing simulated plasma concentration for all participants (OR=1.05, p-value=0.01). Apnea can be a presenting sign of clinically important PDA in the premature infant; the association of increased risk of PDA with increasing maximal plasma caffeine concentrations could reflect the empiric increase in caffeine dosing for treating apnea initially assumed to be due to apnea of prematurity, but later diagnosed as related to a new-onset PDA [18]. Some additional changes in covariate parameter estimates were observed due to sample size differences between the simulated and actual plasma concentration models.

Because of the lack of a comparator group in the available data, known and unknown biases remain in our regression analyses, which should therefore be interpreted with caution.

Table 12-7 Dose Response Modeling Results for Selected CEIs and Caffeine Citrate Exposure Using Simulated Plasma Concentrations

| BPD (N=119) | | NEC (N=35) | | PDA (N=226)
Key Factors (All participants) | Odds Ratio | P-value | Odds Ratio | P-value | Odds Ratio | P-value
Duration of Therapy^1^ (day) | 0.96 | 0.01 | 0.95 | <0.0001 | 0.87 | <0.0001
Simulated Maximum Plasma Concentration During Entire Hospitalization (mg/L)^2^ | 0.98 | 0.11 | N/A | N/A | N/A | N/A
Simulated Maximum Plasma Concentration on Day of CEI^3^ (mg/L) | N/A | N/A | 1.01 | 0.54 | 1.05 | 0.01

1 Duration of caffeine therapy-Participant with Event: Dose days until the event day. Participants without Event: Dose days during the study period.

2 Maximum Plasma Concentration-Participants With Event: the maximum simulated plasma concentration prior to the event. Participants Without Event: the maximum simulated plasma concentration reported during the study period.

3 Most Current Plasma Concentration-Participants With Event: the measure of simulated plasma concentration recorded on the day of the event. Participants Without Event: the last simulated plasma concentration reported during the study period.

Source: Table 14.2.1.3.1.3 (BPD), Table 14.2.1.3.2.3 (NEC) and Table 14.2.1.3.3.3 (PDA)

## 12.2 CAP Trial Safety Results

### 12.2.1 Short-Term Safety Results from CAP Trial

In addition to the lower rates of BPD discussed in Section 11, the CAP Trial showed reduced frequency of medical treatment for PDA (29% vs. 38%, P<0.001); and reduced frequency of surgical closure of PDA (4.5% vs. 13%), P<0.001). The rates of death before hospital discharge, brain injury detected by ultrasound, and NEC did not differ between the 2 groups.

Long-Term Safety Results from CAP Trial Infants from the CAP Trial were followed up at a corrected age of 18 to 21 months for the primary outcome of composite of death before a corrected age of 18 months or survival with cerebral palsy, cognitive delay (defined as a Mental Development Index score of <85 on the Bayley Scales of Infant Development, 2nd ed.), deafness requiring amplification, or bilateral blindness. Follow up assessments began in 2001 and ended in 2007.

Of the 2006 infants enrolled in the CAP Trial, 1869 (93%) infants had adequate data for an analysis of the primary composite outcome. Of these infants, 40% of infants in the caffeine citrate group died or survived with neurodevelopmental disability compared to 46% in the placebo group (P=0.008). The number of infants who would need to be treated with caffeine citrate to prevent one adverse outcome was 16 (95% CI, 9-56). For the individual outcomes, caffeine citrate compared to placebo significantly reduced the incidence of cerebral palsy (4.4% vs. 7.3%, P=0.009) and cognitive delay (34% vs. 38%, P=0.04). The incidence of death, deafness, or blindness did not differ between the 2 groups.

The authors concluded that caffeine citrate significantly improved survival without neurodevelopmental disability at a corrected age of 18-21 months, therefore providing strong evidence that the overall benefits of caffeine citrate therapy outweigh any potential risks up to 2 years after very preterm birth.

### 12.2.2 Survival Without Disability to Age 5 Years Results from CAP Trial

Infants from the CAP Trial were followed to 5 years of age from 2005 to 2011. The primary study outcome was a composite of death before a corrected age of 5 years or survival with 1 or more of the following: motor impairment (defined as a Gross Motor Function Classification System level of 3 to 5), cognitive impairment (defined as a Full Scale IQ<70), behavior problems, poor general health, severe hearing loss, and bilateral blindness.

Of the 2006 infants enrolled in the CAP Trial, 1640 (82%) infants had adequate data for an analysis of the primary composite outcome. The incidence of death or survival with at least 1 impairment did not differ between the caffeine citrate and placebo groups (21% vs. 25%, P=0.09). The rates of individual outcomes of motor impairment, cognitive impairment, behavior problems, poor general health, blindness, or deafness also did not differ between the 2 groups.

The authors concluded that neonatal caffeine citrate therapy was no longer associated with an improved rate of survival without disability in children with very low birth weights who were assessed at 5 years.

## 12.3 Safety Conclusions

The prospective, placebo-controlled CAP Trial showed caffeine citrate to be safe during short-term and long-term follow up. The rates of death before hospital discharge, brain injury diagnosed by ultrasound, and NEC was not different between infants treated with caffeine citrate versus placebo. Mortality also did not differ between caffeine-treated and placebo-treated infants during follow up at 18 to 21 months and at 5 years of age. Survival with neurological impairment also did not differ between the caffeine citrate and placebo groups at the 5-year follow up.

The retrospective data from the Pediatrix, EHR, and PROP datasets demonstrated widespread caffeine citrate use for longer durations in younger premature infants compared to what is described in the drug label. Diagnoses of interest, including NEC, as well as death were infrequent during caffeine citrate exposure. The data provides evidence that use of caffeine citrate in premature infants <33 weeks for longer durations is safe.