# 11 Efficacy Evaluation

## 11.1 Data Analyzed

Published results from the CAP Trial were analyzed to evaluate the short- and long-term efficacy and safety of caffeine citrate therapy in premature infants. Infants from the CAP trial were followed from the time of study enrollment through 5 years of age. Short- and long-term results from the CAP Trial were reported in the following three publications:

1. Schmidt B, Roberts RS, Davis P, . Caffeine therapy for apnea of prematurity. N Engl J Med. 2006;354:2112–21.16707748
2. Schmidt B, Roberts RS, Davis P, . Long-term effects of caffeine therapy for apnea of prematurity. N Engl J Med. 2007;357:1893–902.17989382
3. Schmidt B, Anderson PJ, Doyle LW, . Survival without disability to age 5 years after neonatal caffeine therapy for apnea of prematurity. JAMA. 2012;307:275–82.22253394

## 11.2 Summary of CAP Trial Results for Apnea of Prematurity

The CAP Trial was a randomized, placebo-controlled, double-blind, multicenter clinical trial that enrolled 2006 infants with birth weights of 500-1250 g deemed by their clinicians to be candidates for methylxanthine therapy for apnea of prematurity during the first 10 days of life between 1999 and 2004. Enrolled infants received an intravenous loading dose of 20 mg/kg of caffeine citrate or an equivalent volume of normal saline. This was followed by a daily maintenance intravenous or enteral dose of 5 mg/kg with the option to increase the dose to 10 mg/kg for persistent apnea.

Of the 2006 infants, 1006 infants were randomized to the caffeine citrate group and 1000 infants were randomized into the placebo group. Study infants received their first doses of the study drug at a median postmenstrual age of 28 weeks and were weaned off before reaching a median postmenstrual age of 35 weeks. The median (IQR) number of days of administration was 37 (24-46) in the caffeine citrate group and 36 (23-46) in the placebo group.

Significant efficacy findings among infants in the caffeine citrate group compared to the placebo group included reduced frequency of BPD (36.3% vs. 46.9%, P<0.001); The authors concluded that caffeine citrate therapy for AOP reduces the incidence of BPD with no apparent short-term risks.

## 11.3 Efficacy Conclusions

The CAP Trial found a reduced incidence of bronchopulmonary dysplasia in infants receiving caffeine citrate vs. placebo (36% vs. 47%, P<0.001). The authors concluded that caffeine citrate therapy for AOP reduces the incidence of BPD with no apparent short-term risks.

Retrospective data from the Pediatrix and EHR datasets are discussed in further detail Section 12 and the Pediatrix report (Appendix 16.4.1.1). The incidence of BPD in this caffeine-exposed cohort of infants was 21% (17,769/86,647) and is lower compared to a recent cohort study of 377 preterm infants born between 22 and 30 weeks, which reported 45% infants developing moderate or severe BPD [16]. In the EHR dataset, a total of 119 (37%) infants developed BPD, and a 1-day increase of caffeine citrate use was associated with a 4% decrease in the odds ratio of BPD. In the PROP dataset, 300/794 (38%) caffeine-exposed infants had BPD.