# 10 Study Participants

## 10.1 Disposition of Participants

### 10.1.1 Pediatrix and PROP Data

Separate reports have been prepared for the Pediatrix data (16.4.1.1) and the PROP data (16.4.2.1).

### 10.1.2 EHR Data

For the EHR component of the study, data from infants who received caffeine citrate were collected in consecutive, reverse chronological order, starting with the most recent data available (infants born 12/31/2013) until the desired sample size was reached at each site.

Participant accounting is summarized by site. There were 410 infants recorded in the electronic data system including those at ▬▬▬▬▬

The safety population was comprised of infants who received caffeine citrate per SOC, and included all 410 infants. Per the inclusion criteria defined in the protocol, data was to be collected for premature infants (<28 GA weeks) who had at least 1 day of caffeine citrate therapy. Data regarding caffeine citrate dosing and safety events which occurred outside of the study site were not available for inclusion in this analysis.

#### 10.1.2.1 Data Sets Analyzed

All 410 infants are included in the safety analyses.

#### 10.1.2.2 Demographic and Other Baseline Characteristics

Baseline demographics and other characteristics are summarized by site in Table 14.1.1.

Median postnatal age at start of caffeine citrate was 0 days (range 0 to 44), and median PNA at hospital discharge was 87 days (range 1 to 230). Median GA of the infants was 26 weeks (range 22 to 28). A total of 225 (54.9%) infants were male, and 51 infants (12.4%) were reported to be of Hispanic or Latino ethnicity. A total of 205 infants (50.0%) were of white or Caucasian race; 138 (33.7%) were black or African American; 19 (4.6%) were Asian; 6 (1.5%) were Native Hawaiian or Pacific Islander; 4 (1.0%) were American Indian or Alaska Native; 13 (3.2%) reported more than 1 race; and race was not reported for 25 (6.1%). Median birth weight was 800 g (range 340 to 1460). Infants had a median of 87 days (range 2 to 230) in hospital, and 340 (82.9%) were born in the hospital where they were treated in this study. A total of 287 (70.0%) infants were singleton; 297 (72.4%) were delivered via Caesarean section; 367 (89.5%) were exposed to antenatal steroids; and 389 (94.9%) received surfactant therapy. The median 5-minute Apgar score at birth was 7 (range 1 to 9).

#### 10.1.2.3 Drug Dose and Plasma Concentration

Doses administered and plasma concentration are grouped by site in Table 10-1 and Table 14.3.1. The summary is at participant level during the study period.

The median mean, max, and cumulative daily study dose per kg of participant dosing weight were 8 mg/kg (range 4 to 25); 20 mg/kg (range 5 to 46); and 455 mg/kg (range 20 to 1231). Infants at ▬ received the highest mean, max and cumulative study dose, with a median of 9 mg/kg/day (range 7 to 12), max of 22 mg/kg/day (range 18 to 33), and cumulative of 666 mg/kg (range 107 to 1231). Infants at ▬ had lowest mean, median and cumulative study dose, with a mean of 6 mg/kg, median of 6 mg/kg (range 4 to 22), and cumulative of 263 mg/kg (range 24 to 621)

The median, mean, and max plasma concentration were 18 mg/L (range 2 to 41) and 25 mg/L (range 2 to 44). Infants at ▬ reported the lowest median of mean plasma concentrations at 16 mg/L (range 11 to 24).

Overall, 384 (94%) infants received caffeine citrate for more than 13 days. The median duration of study treatment was 60 days (range 1 to 144). The median number of days prior to discharge that caffeine citrate was discontinued was 27 (range 7 to 156). Infants at ▬ had the longest median study treatment (77 days, with a range of 12 to 144).

Table 10-1 Study Doses and Concentration by Site

| ▬; (N=100) | ▬; (N=108) | ▬; (N=107) | ▬; (N=95) | Total; (N=410)
Mean Study Dose (mg/kg/day)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 9 (1) | 8 (3) | 6 (2) | 9 (3) | 8 (3)
Median (Min, Max) | 9 (7 - 12) | 7 (4 - 13) | 6 (4 - 22) | 9 (4 - 25) | 8 (4 - 25)
Max Study Dose (mg/kg/day)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 23 (4) | 19 (7) | 22 (3) | 22 (4) | 21 (5)
Median (Min, Max) | 22 (18 - 33) | 18 (12 - 46) | 21 (9 - 31) | 20 (5 - 31) | 20 (5 - 46)
Cumulative Study Dose (mg/kg)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 700 (216) | 400 (171) | 269 (128) | 551 (242) | 474 (251)
Median (Min, Max) | 666 (107 - 1231) | 380 (40 - 800) | 263 (24 - 621) | 538 (20 - 1129) | 455 (20 - 1231)
Duration of Study Treatment (days)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 78 (25) | 53 (18) | 49 (23) | 63 (26) | 60 (26)
Median (Min, Max) | 77 (12 - 144) | 55 (5 - 106) | 52 (2 - 94) | 63 (1 - 119) | 60 (1 - 144)
Duration ≥13 days | 99 (99.0%) | 101 (93.5%) | 95 (88.8%) | 89 (93.7%) | 384 (93.7%)
Duration<13 days | 1 (1.0%) | 7 (6.5%) | 12 (11.2%) | 6 (6.3%) | 26 (6.3%)
Number of Days Prior to Discharge that Caffeine citrate was Discontinued (days)
N | 53 | 91 | 79 | 71 | 294
Mean (SD) | 24.2 (15.9) | 36.9 (21.9) | 30.4 (12.6) | 26.9 (22.0) | 30.4 (19.3)
Median (Min, Max) | 21.0 (7.0 – 93.0) | 35.0 (7.0 – 156.0) | 29.0 (7.0 – 61.0) | 18.0 (7.0 – 109.0) | 27.0 (7.0 – 156.0)
Mean Plasma Concentration (mg/L)
N | 24 | 3 | 101 | 46 | 174
Mean (SD) | 25 (7) | 24 (2) | 16 (3) | 24 (8) | 20 (7)
Median (Min, Max) | 26 (2 - 36) | 24 (22 - 26) | 16 (11 - 24) | 24 (7 - 41) | 18 (2 - 41)
Max Plasma Concentration (mg/L)
N | 24 | 3 | 101 | 46 | 174
Mean (SD) | 28 (8) | 24 (2) | 24 (5) | 27 (9) | 25 (7)
Median (Min, Max) | 29 (2 - 39) | 24 (22 - 26) | 24 (12 - 34) | 27 (7 - 44) | 25 (2 - 44)

Source: Table 14.3.1

## 10.2 Protocol Deviations and Waivers

Not applicable.