# 9 Investigational Plan

## 9.1 Overall Design and Plan

To characterize the safety, efficacy, and exposure-response of caffeine citrate in premature infants, the NICHD-2014-CAF01 study included a retrospective review of three data sources (Pediatrix, EHR, and PROP), as well as an analysis of aggregate data published from the CAP Trial.

All four data sources were used to evaluate the safety of caffeine citrate in this population. The EHR data were also used to analyze exposure-response, and the published results of the CAP trial were used to describe efficacy. Table 9-1 provides a schematic of the planned data sources and sample sizes, correlated with the three study objectives.

Table 9-1 Planned Sample Sizes and Study Objectives

| Safety Objective | Efficacy Objective | Exposure-Response Objective
EHR Data | 400 | N/A | 400
Pediatrix Data | 75,000 | N/A | N/A
PROP Data | 750 | N/A | N/A
CAP Trial | 2006 | 1006 | N/A
Totals | 78,156 | 1006 | 400

Source: Protocol

## 9.2 Selection of Study Population

### 9.2.1 Pediatrix

#### Inclusion criteria

1. Discharged from an intensive care nursery managed by the Pediatrix Medical Group from 2005 to 2013
2. <33 weeks gestational age (GA) at birth
3. ≥1 day of caffeine therapy
4. <120 days of age (PNA) at earliest dose of caffeine

#### Exclusion criteria

1. Known major congenital anomaly

### 9.2.2 EHR

#### Inclusion criteria

1. <28 weeks gestational age at birth
2. <120 days of age (PNA) at earliest dose of caffeine
3. ≥1 day of caffeine therapy
4. Admitted to an intensive care nursery from 2005 to 2013

#### Exclusion criteria

1. Known major congenital anomaly

### 9.2.3 PROP

#### Inclusion Criteria

1. Enrolled in PROP
2. ≥1 day of caffeine citrate therapy
3. <120 days of age (PNA) at earliest dose of caffeine citrate

#### Exclusion Criteria

1. None

### 9.2.4 CAP

#### Inclusion criteria

1. 500-1250 g birth weight
2. First 10 days of life
3. Considered by clinician as candidate for methylxanthine therapy

#### Exclusion criteria

1. Dysmorphic feature or congenital anomaly likely to affect neurologic outcome or life expectancy
2. Unlikely to be available for long-term follow-up
3. Previously treated with methylxanthines

## 9.3 Treatments

### 9.3.1 Treatments Administered

The drug of interest in this study was caffeine citrate; however, no treatments were administered.

### 9.3.2 Prior and Concomitant Therapy

No concomitant medications or treatments were administered under this protocol. If available, data on 44 concomitant medications of interest were extracted from the EHR, Pediatrix, and PROP datasets (Table 9-2).

Table 9-2 Concomitant Medications of Interest

1. Furosemide | 12. Fentanyl | 23. Miconazole | 34. Midazolam
2. Bumetanide | 13. Hydromorphone | 24. Nifedipine | 35. Pentobarbital
3. Ethacrynic acid | 14. Methadone | 25. Omeprazole | 36. Phenytoin
4. Hydrochlorothiazide | 15. Amiodarone | 26. Propranolol | 37. Dopamine
5. Chlorothiazide | 16. Amlodipine | 27. Ranitidine | 38. Dobutamine
6. Spironolactone | 17. Dexmedetomidine | 28. Sildenafil | 39. Epinephrine
7. Acetazolamide | 18. Erythromycin | 29. Carbamazepine | 40. Milrinone
8. Indomethacin | 19. Fluconazole | 30. Phenobarbital | 41. Norepinephrine
9. Ibuprofen | 20. Ketoconazole | 31. Rifampin | 42. Phenylephrine
10. Hydrocortisone | 21. Lidocaine | 32. Fosphenytoin | 43. Vasopressin
11. Morphine | 22. Methimazole | 33. Lorazepam | 44. Acetaminophen

Source: Protocol

### 9.3.3 Treatment Compliance

Not applicable.

## 9.4 Safety and Efficacy Variables

### 9.4.1 Pediatrix Variables

Table 9-3 provides a summary of variables for the Pediatrix dataset.

Table 9-3 Pediatrix Variables

| At birth | During hospitalization | Discharge
Demographics
Gestational age | X
Postnatal age | | | X
Infant’s day of admission to hospital | | X
Year of discharge from hospital | | | X
Weight | X
Sex | X
Maternal race/ethnicity | X
Maternal age^*^ | X
Inborn/outborn | X
Mode of delivery | X
5 minute APGAR score | X
Singleton/multiple birth | X
Antenatal steroids | X
Surfactant therapy | | X
Clinical events
Death | | X
BPD | | X
Medical NEC | | X
Surgical NEC | | X
Spontaneous intestinal perforation | | X
Grade II IVH | | X
Grade III or IV IVH | | X
PDA requiring medical treatment^*^ | | X
PDA requiring surgical treatment | | X
Seizure | | X
Arrhythmia | | X
Culture proven bacterial Sepsis^*^ | | X
Laboratory values
Creatinine | | X
Glucose | | X
Sodium | | X
Calcium | | X
AST | | X
ALT | | X
Caffeine citrate^a^
Days of administration | | X
Dose amount | | X
Weight | | X
Concomitant medications of interest^b^
Days of administration | | X

a Every change in caffeine citrate dosing/frequency was recorded

b Per concomitant medicine list (Table 9-2)

* Variables added in response to FDA meeting guidance March 2017 (See Section 9.8.2)

Source: Protocol

### 9.4.2 EHR Variables

Table 9-4 provides a summary of the variables for the EHR data collected via medical chart review at PTN sites.

Table 9-4 EHR Variables

| At birth | During hospitalization | Discharge
Demographics
Birthdate | X
Gestational age | X
Infant’s date of admission to hospital | X
Date of discharge from hospital | | | X
Weight | X
Sex | X
Maternal race/ethnicity | X
Inborn/outborn | X
Mode of delivery | X
5 minute APGAR score | X
Singleton/multiple birth | X
Antenatal steroids | X
Surfactant therapy | | X
Clinical events
Death | | X
BPD | | X
Medical NEC | | X
Surgical NEC | | X
Spontaneous intestinal perforation | | X
Grade II IVH | | X
Grade III or IV IVH | | X
PDA requiring surgical treatment | | X
PDA requiring medical treatment^*^ | | X
Seizure | | X
Arrhythmia | | X
Laboratory values^a^
Plasma caffeine levels | | X
Creatinine | | X
Glucose | | X
Sodium | | X
Calcium | | X
AST | | X
ALT | | X
Caffeine citrate^b^
Days of Administration | | X
Each Dose amount | | X
Weight within 1 week of each administration | | X
Number of days prior to discharge that caffeine citrate was discontinued^*^ | | X
Concomitant medications of interest^c^
Days of administration | | X

a All SOC labs were recorded.

b Every change in caffeine citrate dosing/frequency was to be recorded

c Per concomitant medicine list (Table 9-2)

* Variables added in response to FDA meeting guidance March 2017 (See Section 9.8.2)

Source: Protocol

### 9.4.3 PROP Variables

Table 9-5 provides a summary of variables for the PROP dataset.

Table 9-5 PROP Variables

| At birth | During hospitalization | Discharge | Follow-up (to 12 months)
Demographics
Birth date | X
Gestational age | X
Infant’s date of admission to hospital | X
Date of discharge from hospital | | | X
Weight | X
Sex | X
Maternal race/ethnicity | X
Maternal age^*^ | X
Inborn/outborn | X
Mode of delivery | X
5 minute APGAR score | X
Singleton/multiple birth | X
Antenatal steroids | X
Surfactant therapy | | X
Clinical events
Death | | X
BPD | | X
Medical NEC | | X
Surgical NEC | | X
Spontaneous intestinal perforation | | X
Grade II IVH | | X
Grade III or IV IVH | | X
PDA requiring surgical treatment | | X
Seizure | | X
Arrhythmia | | X
culture proven bacterial sepsis | | X
Caffeine citrate
Days of Administration | | X
Each Dose amount | | X
Weight within 1 week of each administration | | X
Concomitant medications of interest^a^
Days of administration | | X
Post-hospitalization follow-up data^*^
Wheezing | | | | X
Oxygen therapy | | | | X
Ventilator use | | | | X

a Per concomitant medicine list (Table 9-2)

* Variables added in response to FDA meeting guidance March 2017 (See Section 9.8.2)

Source: Protocol

### 9.4.4 CAP Study

The review of published data from the CAP trial included demographics, clinical characteristics, and caffeine citrate administration, as well as mortality, BPD, and NEC.

## 9.5 Data Quality Assurance

For the EHR data, site investigators provided direct access to all trial-related sites, source data/documents, data collection forms, and reports for the purpose of monitoring and auditing by the sponsor, and inspection by local and regulatory authorities. The PI ensured that all study personnel were appropriately trained and applicable documentations were maintained on site. The BPCA DCC implemented data quality control checks that were run on the datasets. Any missing data or data anomalies were communicated for prompt clarification and resolution.

## 9.6 Statistical Methods Planned in the Protocol and Determination of Sample Size

### 9.6.1 Sample Size

For the Pediatrix data, 86,647 infants met the inclusion criteria. This sample size provided for reasonable estimates and 95% CI for safety. If 1% of the infants had a Clinical Event of Interest (CEI), then the 95% CI (exact binomial) for that event within the participant population was 0.93% to 1.06%.

For the EHR data, 410 infants were included in the analyses. Data were collected in reverse chronological order, starting with the most recent data available until the desired sample size was reached. The actual sample size of 410 provided for a reasonable estimate for safety. If 1% of the infants had a CEI, the 95% CI (exact binomial) for that event within the participant population was 0.27% to 2.5%.

For the PROP data, 794 infants were included in the analysis. Sample size was fixed by availability of infants in PROP and provided a reasonable estimate for safety.

### 9.6.2 Analysis Populations

For the Pediatrix database review, participants who met the eligibility criteria in Section 9.2.1 were included in the analysis.

For the EHR data, the safety population included all eligible participants with retrospective data recorded in the data extraction. This population was used for all analyses.

For the PROP data, participants who met the eligibility criteria in Section 9.2.3 were included in the analysis.

### 9.6.3 General Statistical Methodology

For EHR and Pediatrix database analyses, descriptive analysis was used to examine the frequency of clinical events and laboratory events. Frequency of events was analyzed at both the participant level (clinical events) and the participant-day level (laboratory events). The number and percentage of participants who experienced an event and the total number of events were summarized. Analyses in this study are exploratory or descriptive in nature.

For PROP analysis, the frequency of clinical events was summarized descriptively at participant level. The number and percentage of participants who experienced an event and the total number of events were summarized.

For EHR analysis, clinical characteristics were summarized by whether the participant had an event. For EHR and PROP analysis, participant-level descriptive summaries of sex, race/ethnicity, and key endpoints are presented by site.

### 9.6.4 Definition of Clinical Events and Laboratory Events

Clinical Events of Interest (CEIs) and Laboratory Events of Interest (LEIs) were defined in the NICHD-2014-CAF01 protocol for analysis of the Pediatrix, EHR, and PROP data (Appendix 16.1.1). Per the protocol, clinical events and laboratory values were to be attributed to caffeine citrate when they occurred on a day that the infant was exposed to caffeine citrate.

#### 9.6.4.1 Clinical Events of Interest (CEIs)

Table 9-6 summarizes CEIs as defined for the retrospective analysis of the Pediatrix, EHR, and PROP data.

Table 9-6 Clinical Events of Interest

Body System | Mild Event | Severe Event
Respiratory | | - BPD
Gastrointestinal | - Medical NEC | - Surgical NEC; - Spontaneous intestinal perforation
Neurologic | - Grade II IVH | - Grade III or IV IVH; - Seizure
Cardiovascular | - PDA requiring medical treatment | - Arrhythmia; - PDA requiring surgical treatment
General | | - Sepsis (culture proven); - Death

Source: Protocol/Appendix A

Table 9-7 summarizes the definitions of BPD across the three datasets. The definitions of BPD in the Pediatrix and EHR analyses were based on the NICHD definition [15].

Table 9-7 Definitions of BPD Across Datasets

Pediatrix [15] | EHR [15] | PROP
- If <32 weeks GA, received supplemental oxygen or respiratory support (nasal cannula, continuous positive airway pressure, or mechanical ventilation) continuously from a corrected GA of 36 0/7 weeks to 36 6/7 weeks.; - If ≥ 32 weeks GA, received supplemental oxygen or respiratory support continuously from a PNA of 28 to 34 days. | At 36 weeks PMA:; - Received supplemental oxygen (>21% fraction of inspired oxygen, FiO_2_); OR; - Received either positive pressure ventilation or continuous positive airway pressure (e.g., mechanical ventilation, high frequency oscillatory ventilation, CPAP, high flow nasal cannula) | - Defined using the Revised Shennan criteria: infants were identified as having BPD if they required supplemental oxygen >21% at 36 weeks PMA.

Sepsis was defined as a positive blood or cerebrospinal fluid culture during hospitalization for Pediatrix. When multiple cultures with the same organism were obtained within a 21-day period, they were considered to be a single infectious episode.^4^ Coagulase negative Staphylococcus (CoNS) infections were considered to be a true infection (i.e. not a contaminant) if 2 positive cultures were drawn within a 4-day period, 3 positive cultures were drawn within a 7-day period, or 4 positive cultures were drawn within a 10-day period.^4^

For PROP, sepsis was defined as a positive blood culture during hospitalization.

Sepsis was not a variable in the EHR study.

Table 9-8 summarizes the definitions of sepsis across the three datasets.

Table 9-8 Definitions of Sepsis Across Datasets

Pediatrix [4] | EHR | PROP
- Positive blood or cerebrospinal fluid culture during hospitalization.; - Multiple cultures with the same organism within a 21-day period were considered to be a single infectious episode.; - Coagulase negative Staphylococcus were considered to be a true infection if 2 positive cultures were drawn within a 4-day period, 3 within a 7-day period, or 4 within a 10-day period | - Sepsis was not a variable in the EHR study. | - Positive blood culture during hospitalization.

An infant was considered to have arrhythmia if given the following diagnoses during hospitalization:

1. Supraventricular tachycardia
2. Atrial flutter
3. Atrial fibrillation
4. Ventricular tachycardia
5. Ventricular fibrillation
6. Torsades de pointes
7. Second degree atrioventricular block (Type 1 or 2)
8. Third degree atrioventricular block (Complete)

#### 9.6.4.2 Laboratory Events of Interest (LEIs)

Table 9-9 summarizes LEIs as defined for the retrospective analyses of the Pediatrix, EHR, and PROP data.

Table 9-9 Laboratory Values of Interest

Laboratory Values | Mild Event | Severe Event
Serum electrolytes
Hyperglycemia | >150 mg/dL | >400 mg/dL
Hypoglycemia | <40 mg/dL | <20 mg/dL
Hypernatremia | >150 mmol/L | >160 mmol/L
Hyponatremia | <125 mmol/L | <115 mmol/L
Hypercalcemia (iCa) | >12.0 mg/dL (> 1.5 mmol/L) | >14.0 mg/dL (> 1.6 mmol/L)
Hypocalcemia (iCa) | <6.0 mg/dL (< 0.9 mmol/L) | <4.0 mg/dL (< 0.8 mmol/L)
Renal dysfunction
Elevated creatinine | >1.7 mg/dL | >3.0 mg/dL
Liver dysfunction
Elevated AST | >400 U/L | >1000 U/L
Elevated ALT | >200 U/L | >1000 U/L

Source: Protocol/Appendix B

## 9.7 Dose Response Summaries of Events of Special Interest

### 9.7.1 Dose Response Analyses of Clinical Events of Interest (CEIs)

Dose-response analyses of CEIs were conducted at participant level. The GA and PNA, duration of therapy, sex, birth weight, 5-minute Apgar score, calculated cumulative dose, maximum dose, most current daily dose, maximum plasma levels of caffeine and most current plasma levels of caffeine close to the event were summarized for each event by whether the event occurred or did not occur. BPD was evaluated at 36 weeks of PMA assessment, and other events were on a day of caffeine citrate dosing. Participants who died or were discharged prior to 36 weeks PMA were excluded from BPD analysis. Descriptive summaries for each CEI by site and severity were also reported.

The effect of dose and plasma levels on BPD, NEC and PDA adjusted for important factors of interest were evaluated via multivariable logistic regression models. Adjusted odds ratio (OR), 95% confidence limit, and p-values were calculated using logistic regression models. Due to high correlation between dose and plasma levels, separate logistic regression models were developed.

Independent factors in all logistic regression analyses included site, GA, birth weight, duration of therapy (through day of event or maximum follow up, if the participant did not experience an event) and concomitant medications by classification. In the models evaluating effect of dose on select CEIs, mean study dose was included (through day of event or maximum follow up, if the participant did not experience an event). The most current plasma level of caffeine close to the event date was included in the plasma models for NEC and PDA. For participants that did not develop NEC or PDA, the last reported plasma level was used in the regression analyses. The maximum plasma level until the event date for participants who experienced BPD, or overall for those who did not, was included in the model evaluating effect of plasma level on BPD.

### 9.7.2 Dose Response Analyses of Laboratory Events of Interest (LEI)

Analyses of Laboratory Events of Interest (LEIs) were conducted at the participant level and performed using descriptive summaries of the events. The GA and PNA, duration of therapy, sex, birth weight, 5-minute Apgar score, calculated cumulative dose, maximum dose, most current daily dose close to the event, maximum plasma levels of caffeine and most current plasma levels of caffeine were summarized for each event by whether the event occurred or did not occur on a day of caffeine citrate dosing. The descriptive summaries for each LEI by site and severity were also reported. If a laboratory event occurred multiple times at different severity levels during the study in the same participant, the first occurrence of the most severe event was used in the dose response analysis for that participant.

## 9.8 Changes in the Conduct of the Study or the Planned Analyses

### 9.8.1 Changes in Conduct of the Study

Study activity was initiated under version 2.0 of the protocol, dated August 3, 2015 (Appendix 16.1.1), and there were no further amendments to the protocol.

### 9.8.2 Changes in Planned Analyses

Table 14.2.1.1.2 summarizes all clinical events occurring after start of caffeine citrate, including events that occurred on days when the infant was not exposed to caffeine.

The definition of diagnosis Adverse Events (AEs) and laboratory AEs defined in the SAP are the same as CEIs attributed to caffeine and LEIs attributed to caffeine as defined in the protocol.

## 9.9 Additions to the Planned Analyses

After consultation with FDA (Meeting Preliminary Comments from the Agency dated March 16, 2017 and additional email communication dated April 20, 2017), maternal age, sepsis, and safety data for medical PDA were added to the Pediatrix analysis (Appendix 16.4.1.1, Table 3); maternal age and post-hospital follow-up data were added to the PROP analysis (Appendix 16.4.2.1, Table 1 and Table 6); and safety data for medical PDA (Tables 14.2.1.1.1 and 14.2.1.1.2) and the number of days prior to discharge that caffeine was discontinued (Table 14.3.1) was added to the EHR analysis.

To support the dose response models for select CEIs (Section 12.1.2.4), additional analyses were performed to evaluate simulated plasma concentration as predictor of BPD, NEC and PDA events for the full safety population adjusted for demographic and clinical covariates. The methodology used to simulate plasma concentrations is described in Appendix 16.5.2.