# 8 Study Objectives

The objectives of the NICHD-2014-CAF01 study were:

1. To characterize safety of caffeine citrate.
2. To characterize efficacy of caffeine citrate.
3. To evaluate the caffeine citrate exposure-response relationship.