# 7 Introduction

Section 409I of the Public Health Service Act, also known as the Best Pharmaceuticals for Children Act (BPCA), mandates the National Institutes of Health (NIH) to prioritize therapeutic areas in critical need for pediatric labeling; to sponsor pediatric clinical trials; and to submit these data to FDA for consideration for labeling changes. Under the BPCA, the National Institute of Child Health and Human Development (NICHD) awarded a contract to Duke University, which established the Pediatric Trials Network (PTN) through its Duke Clinical Research Institute (DCRI). The NICHD awarded a separate contract to The Emmes Corporation to serve as the BPCA Data Coordinating Center (DCC).

## 7.1 Caffeine Citrate and Apnea of Prematurity (AOP)

The NICHD prioritized caffeine citrate for investigation of dosing and long-term safety when used in the treatment of apnea of prematurity (AOP) [1]. Infants with AOP experience frequent episodes of apnea, resulting in hypoxemia and bradycardia, and placing the infant at risk for prolonged mechanical ventilation, retinopathy of prematurity (ROP), bronchopulmonary dysplasia (BPD), and long-term neurodevelopmental impairment (NDI) [2–4]. Approximately 85% of infants born <34 weeks gestational age (GA) and almost all infants born <29 GA develop AOP [5, 6].

One of the most common non-antimicrobial medications used in the neonatal intensive care unit (NICU), caffeine citrate is labeled for short-term treatment of AOP between 28 and <33 weeks gestational age (GA). However, in clinical practice, caffeine citrate is frequently used off-label in more immature (e.g. lower GA) infants, including those as early as 22 weeks GA [7,8]. In addition, clinicians also use a higher dose and longer duration of exposure than the label recommendation of single loading doses of 20 mg/kg intravenously and maintenance doses of 5 mg/kg administered intravenously or orally every 24 hours for 10 days [7,8].

The caffeine citrate label was last reviewed in 1999 [8]. Subsequent studies have examined the safety and efficacy of caffeine citrate in neonatal populations [3,5,7,9], and the Caffeine for Apnea of Prematurity (CAP) trial – a randomized, placebo-controlled, multicenter trial – has provided significant short- and long-term safety and efficacy data [10–12]. The caffeine citrate label warns of an association of caffeine citrate and necrotizing enterocolitis (NEC) based on the findings from an older randomized, double-blind, placebo-controlled trial involving 85 premature infants [13]; however, the larger, placebo controlled CAP trial did not find a significant difference in incidence of NEC between the caffeine citrate and control groups [10].

The current medical literature indicates a significant gap between the caffeine citrate label and contemporary clinical practice. A comprehensive literature review is included in the appendices (Appendix 16.4.3). The NICHD-2014-CAF01 study was conducted to determine opportunities for improving the pediatric labeling of caffeine citrate.

## 7.2 Data Sources for This Report

The study includes retrospective analysis of data of premature infants treated with caffeine citrate per standard of care (SOC), as well as the published results from the CAP trial.

### 7.2.1 Retrospective Datasets

The retrospective analysis includes data from three sources:

#### 7.2.1.1 Pediatrix Medical Group (Pediatrix) Administrative Database

Data were extracted from the electronic medical records of Pediatrix Medical Group. The Pediatrix database is prospectively created from electronic health records of infants admitted to >300 NICUs in the US. It is one of the largest repositories of data for neonatal medicine. The database includes approximately 20% of all NICU patients in the US and >90,000 NICU admissions annually. A more detailed description of study procedures, analysis of the Pediatrix database, and results are provided in Appendix 16.4.1.1.

#### 7.2.1.2 Electronic Health Record (EHR) Data Extraction

Data were extracted from electronic health records (EHRs) from four PTN sites: ▬▬▬▬▬

#### 7.2.1.3 Prematurity and Respiratory Outcome (PROP) Data

The NICHD-2014-CAF01 study includes analysis of data from the Prematurity and Respiratory Outcomes Program (PROP), an observational, prospective cohort study sponsored by the NIH and the National Heart, Lung, and Blood Institute (NHLBI) to improve the management of respiratory complications of premature and low birth weight infants [14]. The PROP study gathered data from premature infants (23 - 28 weeks gestation) admitted to a consortium of 13 medical centers in the U.S. between 2011 and 2014. An analysis of PROP data is included in Appendix 16.4.2.1.

### 7.2.2 CAP Study

Published data from the CAP trial have been summarized as part of this study. The CAP trial randomized 2006 infants with a mean GA of 27 (standard deviation ± 2) to treatment with caffeine citrate or placebo in a 1:1 ratio. Infants in the active treatment group were given a loading dose of 20 mg/kg, followed by a daily maintenance dose of 5 mg/kg.

## 7.3 Clinical Study Report (CSR) Structure

Sections 8 and 9 of this Draft CSR present the objectives and investigational plan for the NICHD-2014-CAF01 study as a whole, including the EHR, Pediatrix, PROP, and CAP data. EHR data collected from PTN sites are presented in Sections 10, 11, 12 and 14 of this CSR; separate reports analyzing the Pediatrix data (16.4.1.1) and the PROP data (16.4.2.1) are included in the Section 16 appendices.