# 15 Reference List

1 National Institutes of Health. Best Pharmaceuticals of Children Act (BPCA) priority list of needs in pediatric therapeutics. 2015. https://bpca.nichd.nih.gov/prioritization/priority_lists/Pages/priority_list.aspx
2 Di Fiore JM, Bloom JN, Orge F, . A higher incidence of intermittent hypoxemic episodes is associated with severe retinopathy of prematurity. J Pediatr. 2010;157:69–73.20304417
3 Janvier A, Khairy M, Kokkotis A, Cormier C, Messmer D, Barrington KJ. Apnea is associated with neurodevelopmental impairment in very low birth weight infants. J Perinatal. 2004;24(12):763–768.
4 Taylor HG, Klein N, Schatschneider C, Hack M. Predictors of early school age outcomes in very low birth weight children. J Dev Behav Pediatr. 1998;19(4):235–243.9717132
5 Zhao J, Gonzalez F, Mu D. Apnea of prematurity: from cause to treatment. Eur J Pediatr. 2011;170(9):1097–1105.21301866
6 Barrington K, Finer N. The natural history of the appearance of apnea of prematurity. Pediatr Res. 1991;29:372–375.1852531
7 Natarajan G, Botica ML, Thomas R, Aranda JV. Therapeutic drug monitoring for caffeine in preterm neonates: an unnecessary exercise? Pediatrics. 2007;119(5):936–940.17473094
8 US Food and Drug Administration, Center for Drug Evaluation and Research. CAFCIT NDA 020793 medical review (Application Number 20-793), August 23, 1999.
9 Aranda JV, Beharry K, Valencia GB, Natarajan G, Davis J. Caffeine impact on neonatal morbidities. J Matern Fetal Neonatal Med. 2010;23:(Suppl 3):20–23.20873976
10 Schmidt B, Roberts RS, Davis P, . Caffeine therapy for apnea of prematurity. N Engl J Med. 2006;354(2):2112–2121.16707748
11 Schmidt B, Roberts RS, Davis P, . Long-term effects of caffeine therapy for apnea of prematurity. N Engl J Med. 2007;357(19):1893–1902.17989382
12 Schmidt B, Anderson PJ, Doyle LW, . Survival without disability to age 5 years after neonatal caffeine therapy for apnea of prematurity. JAMA. 2012;307(3):275–282.22253394
13 Erenberg A, Leff RD, Haack DG, Mosdell KW, Hicks GM, Wynne BA. Caffeine citrate for the treatment of apnea of prematurity: a double-blind, placebo-controlled study. Pharmacotherapy. 2000;20(6):644–652.10853619
14 Pryhuber GS, Maitre NL, Ballard RA, . Prematurity and respiratory outcomes program (PROP): study protocol of a prospective multicenter study of respiratory outcomes of preterm infants in the United States. BMC Pediatr. 2015;15:37.25886363
15 Jobe AH, Bancalari E. Bronchopulmonary dysplasia. Am J Respir Crit Care Med. 2001;163(7):1723–1729.11401896
16 Farstad T, Bratlid D, Medbo S, Markestad T; Norwegian Extreme Prematurity Study Group. Bronchopulmonary dysplasia - prevalence, severity and predictive factors in a national cohort of extremely premature infants. Acta Paediatr. 2011;100(1):53–58.20653607
17 Charles BG, Townsend SR, Steer PA, Flenady VJ, Gray PH, Shearman A. Caffeine citrate treatment for extremely premature infants with apnea: population pharmacokinetics, absolute bioavailability, and implications for therapeutic drug monitoring. Ther Drug Monit. 2008;30(6):709–16.19057373
18 Zhao J, Gonzalez F, Mu D. Apnea of prematurity: from cause to treatment. Eur J Pediatr. 2011;170(9):1097–1105.21301866