# 14 Tables, Figures, and Graphs Referred to but not Included in the Text

## 14.1 Demographic Data (EHR Data)

Table Number | Population | Table Title / Summary
14.1.1 | Safety | Summary of Baseline Demographics by Site

## 14.2 Safety Data (EHR Data)

Table Number | Population | Table Title / Summary
14.2.1.1.1.1 | Safety | Summary of Clinical Events of Interest Attributed to Caffeine Exposure by Site
14.2.1.1.1.2 | Safety | Summary of Body System for Clinical Events of Interest Attributed to Caffeine Exposure by Site and Severity
14.2.1.1.2.1 | Safety | Summary of Clinical Events of Interest Reported After Initiation of Caffeine Therapy by Site
14.2.1.1.2.2 | Safety | Summary of Body System for Clinical Events of Interest Reported After Initiation of Caffeine Therapy by Site and Severity
14.2.1.2.1 | Safety | Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-Death
14.2.1.2.2 | Safety | Dose Response Analysis of Clinical Events of Interest – BPD
14.2.1.2.3 | Safety | Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-Medical NEC
14.2.1.2.4 | Safety | Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-Surgical NEC
14.2.1.2.5 | Safety | Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-Spontaneous Intestinal Perforation
14.2.1.2.6 | Safety | Dose Response Analysis of Clinical Events of Interest - Grade II Intraventricular Hemorrhage
14.2.1.2.7 | Safety | Dose Response Analysis of Clinical Events of Interest - Grade III or IV Intraventricular Hemorrhage
14.2.1.2.8 | Safety | Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-PDA Requiring Surgical Treatment
14.2.1.2.9 | Safety | Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-Seizure
14.2.1.3.1.1 | Safety | Study Dose as a Predictor of BPD Adjusted for Other Factors of Interest
14.2.1.3.1.2 | Safety | Maximum Plasma Concentration as a Predictor of BPD Adjusted for Other Factors of Interest
14.2.1.3.1.3 | Safety | Simulated Maximum Plasma Concentration as Predictor of BPD Adjusted for Other Factors of Interest
14.2.1.3.2.1 | Safety | Study Dose as a Predictor of NEC Adjusted for Other Factors of Interest
14.2.1.3.2.2 | Safety | Most Current Plasma Concentration as a Predictor of NEC Adjusted for Other Factors of Interest
14.2.1.3.2.3 | Safety | Simulated Current Plasma Concentration as Predictor of NEC Adjusted for Other Factors of Interest
14.2.1.3.3.1 | Safety | Study Dose as a Predictor of PDA Adjusted for Other Factors of Interest
14.2.1.3.3.2 | Safety | Most Current Plasma Concentration as a Predictor of PDA Adjusted for Other Factors of Interest
14.2.1.3.3.3 | Safety | Simulated Current Plasma Concentration as Predictor of PDA Adjusted for Other Factors of Interest
14.2.2.1.1 | Safety | Summary of Laboratory Events of Interest Attributed to Caffeine Exposure by Site and Severity
14.2.2.1.2 | Safety | Summary of Classification for Laboratory Events of Interest Attributed to Caffeine Exposure by Site and Severity
14.2.2.2 | Safety | Dose Response Analysis for Laboratory Events of Interest Attributed to Caffeine Exposure

## 14.3 Dosing Data (EHR Data)

Table Number | Population | Table Title / Summary
14.3.1 | Safety | Summary of Study Doses and Concentration by Site
14.3.2 | Safety | Concomitant Medications by Drug Classification, Drug Name and Site Safety Population

Table 14.1.1 Summary of Baseline Demographics by Site Safety Population

| Site | | | | Total; (N=410)
| ▬; (N=100) | ▬; (N=108) | ▬; (N=107) | ▬; (N=95) | Total; (N=410)
Postnatal age at start caffeine (days)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 2 (6) | 0 (1) | 1 (3) | 1 (1) | 1 (4)
Median (Min, Max) | 1 (0 - 44) | 0 (0 - 4) | 0 (0 - 28) | 0 (0 - 4) | 0 (0 - 44)
Postnatal age at hospital discharge (days)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 97 (29) | 85 (36) | 73 (36) | 86 (39) | 85 (36)
Median (Min, Max) | 95 (14 - 230) | 87 (5 - 218) | 81 (1 - 149) | 83 (1 - 194) | 87 (1 - 230)
Gestational age (weeks)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 25.5 (1.3) | 25.4 (1.3) | 25.4 (1.3) | 25.6 (1.4) | 25.5 (1.3)
Median (Min, Max) | 26.0 (23.0 - 27.0) | 25.0 (22.0 - 27.0) | 26.0 (23.0 - 27.0) | 26.0 (22.0 - 28.0) | 26.0 (22.0 - 28.0)
Gender
Male | 57 (57.0%) | 60 (55.6%) | 54 (50.5%) | 54 (56.8%) | 225 (54.9%)
Female | 43 (43.0%) | 48 (44.4%) | 53 (49.5%) | 41 (43.2%) | 185 (45.1%)
Ethnicity
Hispanic or Latino | 1 (1.0%) | 13 (12.0%) | 10 (9.3%) | 27 (28.4%) | 51 (12.4%)
Not Hispanic or Latino | 99 (99.0%) | 95 (88.0%) | 95 (88.8%) | 62 (65.3%) | 351 (85.6%)
Not reported | 0 | 0 | 2 (1.9%) | 6 (6.3%) | 8 (2.0%)
Race
White or Caucasian | 71 (71.0%) | 46 (42.6%) | 40 (37.4%) | 48 (50.5%) | 205 (50.0%)
Black or African American | 20 (20.0%) | 45 (41.7%) | 57 (53.3%) | 16 (16.8%) | 138 (33.7%)
Asian | 7 (7.0%) | 0 | 4 (3.7%) | 8 (8.4%) | 19 (4.6%)
Native Hawaiian or Pacific Islander | 0 | 6 (5.6%) | 0 | 0 | 6 (1.5%)
American Indian or Alaska Native | 2 (2.0%) | 2 (1.9%) | 0 | 0 | 4 (1.0%)
More Than 1 Race | 0 | 9 (8.3%) | 0 | 4 (4.2%) | 13 (3.2%)
Not reported | 0 | 0 | 6 (5.6%) | 19 (20.0%) | 25 (6.1%)
Birth weight (grams)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 802 (196) | 825 (198) | 781 (211) | 850 (207) | 814 (204)
Median (Min, Max) | 800 (370 - 1220) | 780 (430 - 1460) | 780 (360 - 1390) | 859 (340 - 1270) | 800 (340 - 1460)
Singleton
No | 37 (37.0%) | 18 (16.7%) | 37 (34.6%) | 31 (32.6%) | 123 (30.0%)
Yes | 63 (63.0%) | 90 (83.3%) | 70 (65.4%) | 64 (67.4%) | 287 (70.0%)
Inborn
No | 13 (13.0%) | 17 (15.7%) | 0 | 40 (42.1%) | 70 (17.1%)
Yes | 87 (87.0%) | 91 (84.3%) | 107 (100.0%) | 55 (57.9%) | 340 (82.9%)
Mode of delivery
Vaginal | 25 (25.0%) | 45 (41.7%) | 28 (26.2%) | 15 (15.8%) | 113 (27.6%)
Caesarean Section | 75 (75.0%) | 63 (58.3%) | 79 (73.8%) | 80 (84.2%) | 297 (72.4%)
Five min Apgar
N | 98 | 107 | 107 | 94 | 406
Mean (SD) | 6 (2) | 7 (2) | 7 (2) | 7 (2) | 7 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (1 - 9) | 8 (1 - 9) | 8 (1 - 9) | 7 (1 - 9)
Antenatal steroids
No | 6 (6.0%) | 17 (15.7%) | 8 (7.5%) | 12 (12.6%) | 43 (10.5%)
Yes | 94 (94.0%) | 91 (84.3%) | 99 (92.5%) | 83 (87.4%) | 367 (89.5%)
Surfactant therapy
No | 3 (3.0%) | 2 (1.9%) | 13 (12.1%) | 3 (3.2%) | 21 (5.1%)
Yes | 97 (97.0%) | 106 (98.1%) | 94 (87.9%) | 92 (96.8%) | 389 (94.9%)
Length of stay in hospital (days)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 95 (28) | 86 (36) | 74 (36) | 87 (39) | 85 (36)
Median (Min, Max) | 95 (15 - 230) | 87 (5 - 219) | 82 (2 - 150) | 83 (2 - 195) | 87 (2 - 230)

Note: Length of stay in hospital is calculated as (discharge date) - (first dose date) + 1 day.

Table 14.2.1.1.1.1 Summary of Clinical Events of Interest Attributed to Caffeine Exposure by Site Safety Population

| Site | | | | Total; (N=410)
| ▬; (N=100) | ▬; (N=108) | ▬; (N=107) | ▬; (N=95) | Total; (N=410)
Death
Number of Participants | 0 | 2 (1.9%) | 4 (3.7%) | 3 (3.2%) | 9 (2.2%)
BPD
Number of Participants at Risk of BPD^1^ | 94 | 85 | 73 | 73 | 325
Number of Participants with BPD | 46 (48.9%) | 23 (27.1%) | 21 (28.8%) | 29 (39.7%) | 119 (36.6%)
Medical NEC
Number of Events | 1 | 9 | 4 | 5 | 19
Number of Participants | 1 (1.0%) | 9 (8.3%) | 4 (3.7%) | 5 (5.3%) | 19 (4.6%)
Surgical NEC
Number of Events | 4 | 3 | 8 | 3 | 18
Number of Participants | 4 (4.0%) | 3 (2.8%) | 8 (7.5%) | 3 (3.2%) | 18 (4.4%)
Spontaneous Intestinal Perforation
Number of Events | 5 | 7 | 5 | 2 | 19
Number of Participants | 5 (5.0%) | 7 (6.5%) | 5 (4.7%) | 2 (2.1%) | 19 (4.6%)
Grade II Intraventricular Hemorrhage
Number of Events | 7 | 7 | 8 | 7 | 29
Number of Participants | 7 (7.0%) | 7 (6.5%) | 8 (7.5%) | 7 (7.4%) | 29 (7.1%)
Grade III or IV Intraventricular Hemorrhage
Number of Events | 17 | 10 | 15 | 10 | 52
Number of Participants | 17 (17.0%) | 10 (9.3%) | 15 (14.0%) | 10 (10.5%) | 52 (12.7%)
PDA Requiring Surgical Treatment
Number of Events | 14 | 21 | 9 | 6 | 50
Number of Participants | 14 (14.0%) | 21 (19.4%) | 9 (8.4%) | 6 (6.3%) | 50 (12.2%)
PDA Requiring Medical Treatment^2^
Number of Events | 69 | 61 | 48 | 36 | 214
Number of Participants | 69 (69.0%) | 61 (56.5%) | 48 (44.9%) | 36 (37.9%) | 214 (52.2%)
PDA Requiring Either Medical or Surgical Treatment
Number of Events | 74 | 67 | 48 | 37 | 226
Number of Participants | 74 (74.0%) | 67 (62.0%) | 48 (44.9%) | 37 (38.9%) | 226 (55.1%)
Seizure
Number of Events | 2 | 9 | 2 | 0 | 13
Number of Participants | 2 (2.0%) | 9 (8.3%) | 2 (1.9%) | 0 | 13 (3.2%)
Arrhythmia
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0

Note: Clinical events are attributed to caffeine if they are presented on a day that the participant was exposed to caffeine except for BPD and intraventricular hemorrhage.

Only clinical events attributed to caffeine that occurred after the first day of caffeine dosing are included.

1 Per BPD definition, participants discharged or transferred from hospital before 36 weeks of PMA are excluded from this analysis.

2 Participants used Ibuprofen or Indomethacin as concomitant medication are considered to have PDA requiring medical treatment. Doses of both medications given on birth date and next day are excluded.

Table 14.2.1.1.1.2 Summary of Body System for Clinical Events of Interest Attributed to Caffeine Exposure by Site and Severity Safety Population

| ▬; (N=100) | | ▬; (N=108) | | ▬; (N=107) | | ▬; (N=95) | | Total; (N=410)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Respiratory
Number of Participants at Risk of BPD^1^ | N/A | 94 | N/A | 85 | N/A | 73 | N/A | 73 | N/A | 325
Number of Participants with BPD | N/A | 46 (48.9%) | N/A | 23 (27.1%) | N/A | 21 (28.8%) | N/A | 29 (39.7%) | N/A | 119 (36.6%)
Gastrointestinal
Number of Events | 1 | 9 | 9 | 10 | 4 | 13 | 5 | 5 | 19 | 37
Number of Participants | 1 (1.0%) | 8 (8.0%) | 9 (8.3%) | 10 (9.3%) | 4 (3.7%) | 13 (12.1%) | 5 (5.3%) | 4 (4.2%) | 19 (4.6%) | 35 (8.5%)
Neurologic
Number of Events | 7 | 19 | 7 | 19 | 8 | 17 | 7 | 10 | 29 | 65
Number of Participants | 7 (7.0%) | 17 (17.0%) | 7 (6.5%) | 15 (13.9%) | 8 (7.5%) | 15 (14.0%) | 7 (7.4%) | 10 (10.5%) | 29 (7.1%) | 57 (13.9%)
Cardiovascular
Number of Events | N/A | 83 | N/A | 82 | N/A | 57 | N/A | 42 | N/A | 264
Number of Participants | N/A | 74 (74.0%) | N/A | 67 (62.0%) | N/A | 48 (44.9%) | N/A | 37 (38.9%) | N/A | 226 (55.1%)
General
Number of Events | N/A | 0 | N/A | 2 | N/A | 4 | N/A | 3 | N/A | 9
Number of Participants | N/A | 0 | N/A | 2 (1.9%) | N/A | 4 (3.7%) | N/A | 3 (3.2%) | N/A | 9 (2.2%)

Note: Clinical events are attributed to caffeine if they are presented on a day that the participant was exposed to caffeine except for BPD and intraventricular hemorrhage.

Only clinical events attributed to caffeine that occurred after the first day of caffeine dosing are included.

N/A represents an event not defined in the protocol.

1 Per BPD definition, participants discharged or transferred from hospital before 36 weeks of PMA are excluded from this analysis.

2 Participants used Ibuprofen or Indomethacin as concomitant medication are considered to have PDA requiring medical treatment. Doses of both medications given on birth date and next day are excluded.

Table 14.2.1.1.2.1 Summary of Clinical Events Reported after Initiation of Caffeine Therapy by Site Safety Population

| Site | | | | Total; (N=410)
| ▬; (N=100) | ▬; (N=108) | ▬; (N=107) | ▬; (N=95) | Total; (N=410)
Death
Number of Participants | 3 (3.0%) | 7 (6.5%) | 9 (8.4%) | 9 (9.5%) | 28 (6.8%)
BPD
Number of Participants at Risk of BPD^1^ | 94 | 85 | 73 | 73 | 325
Number of Participants with BPD | 46 (48.9%) | 23 (27.1%) | 21 (28.8%) | 29 (39.7%) | 119 (36.6%)
Medical NEC
Number of Events | 1 | 9 | 4 | 5 | 19
Number of Participants | 1 (1.0%) | 9 (8.3%) | 4 (3.7%) | 5 (5.3%) | 19 (4.6%)
Surgical NEC
Number of Events | 5 | 5 | 9 | 5 | 24
Number of Participants | 5 (5.0%) | 5 (4.6%) | 9 (8.4%) | 5 (5.3%) | 24 (5.9%)
Spontaneous Intestinal Perforation
Number of Events | 6 | 8 | 7 | 3 | 24
Number of Participants | 6 (6.0%) | 8 (7.4%) | 7 (6.5%) | 3 (3.2%) | 24 (5.9%)
Grade II Intraventricular Hemorrhage
Number of Events | 7 | 7 | 8 | 7 | 29
Number of Participants | 7 (7.0%) | 7 (6.5%) | 8 (7.5%) | 7 (7.4%) | 29 (7.1%)
Grade III or IV Intraventricular Hemorrhage
Number of Events | 17 | 10 | 15 | 10 | 52
Number of Participants | 17 (17.0%) | 10 (9.3%) | 15 (14.0%) | 10 (10.5%) | 52 (12.7%)
PDA Requiring Surgical Treatment
Number of Events | 17 | 24 | 10 | 8 | 59
Number of Participants | 17 (17.0%) | 24 (22.2%) | 10 (9.3%) | 8 (8.4%) | 59 (14.4%)
PDA Requiring Medical Treatment^2^
Number of Events | 70 | 69 | 51 | 37 | 227
Number of Participants | 70 (70.0%) | 69 (63.9%) | 51 (47.7%) | 37 (38.9%) | 227 (55.4%)
PDA Requiring Either Medical or Surgical Treatment
Number of Events | 77 | 74 | 51 | 40 | 242
Number of Participants | 77 (77.0%) | 74 (68.5%) | 51 (47.7%) | 40 (42.1%) | 242 (59.0%)
Seizure
Number of Events | 4 | 9 | 2 | 0 | 15
Number of Participants | 3 (3.0%) | 9 (8.3%) | 2 (1.9%) | 0 | 14 (3.4%)
Arrhythmia
Number of Events | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0

Note: Clinical events reported after initiation of caffeine therapy include all events during the study period.

1 Per BPD definition, participants discharged or transferred from hospital before 36 weeks of PMA are excluded from this analysis.

2 Participants used Ibuprofen or Indomethacin as concomitant medication are considered to have PDA requiring medical treatment. Doses of both medications given on birth date and next day are excluded.

Table 14.2.1.1.2.2 Summary of Body System for Clincal Events Reported after Initiation of Caffeine Therapyby Site and Severity Safety Population

| ▬; (N=100) | | ▬; (N=108) | | ▬; (N=107) | | ▬; (N=95) | | Total; (N=410)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Respiratory
Number of Participants at Risk of BPD* | N/A | 94 | N/A | 85 | N/A | 73 | N/A | 73 | N/A | 325
Number of Participants with BPD | N/A | 46 (48.9%) | N/A | 23 (27.1%) | N/A | 21 (28.8%) | N/A | 29 (39.7%) | N/A | 119 (36.6%)
Gastrointestinal
Number of Events | 1 | 11 | 9 | 13 | 4 | 16 | 5 | 8 | 19 | 48
Number of Participants | 1 (1.0%) | 10 (10.0%) | 9 (8.3%) | 13 (12.0%) | 4 (3.7%) | 16 (15.0%) | 5 (5.3%) | 7 (7.4%) | 19 (4.6%) | 46 (11.2%)
Neurologic
Number of Events | 7 | 21 | 7 | 19 | 8 | 17 | 7 | 10 | 29 | 67
Number of Participants | 7 (7.0%) | 17 (17.0%) | 7 (6.5%) | 15 (13.9%) | 8 (7.5%) | 15 (14.0%) | 7 (7.4%) | 10 (10.5%) | 29 (7.1%) | 57 (13.9%)
Cardiovascular
Number of Events | N/A | 87 | N/A | 93 | N/A | 61 | N/A | 45 | N/A | 286
Number of Participants | N/A | 77 (77.0%) | N/A | 74 (68.5%) | N/A | 51 (47.7%) | N/A | 40 (42.1%) | N/A | 242 (59.0%)
General
Number of Events | N/A | 3 | N/A | 7 | N/A | 9 | N/A | 9 | N/A | 28
Number of Participants | N/A | 3 (3.0%) | N/A | 7 (6.5%) | N/A | 9 (8.4%) | N/A | 9 (9.5%) | N/A | 28 (6.8%)

Note: Clinical events reported after initiation of caffeine therapy include all events during the study period.

Only clinical events attributed to caffeine that occurred after the first day of caffeine dosing are included.

N/A represents an event not defined in the protocol.

1 Per BPD definition, participants discharged or transferred from hospital before 36 weeks of PMA are excluded from this analysis.

2 Participants used Ibuprofen or Indomethacin as concomitant medication are considered to have PDA requiring medical treatment. Doses of both medications given on birth date and next day are excluded.

Table 14.2.1.2.1 Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-Death Safety Population

| Lived; (n=401) | Died^*^; (n=9)
Birth Gestation (weeks)
N | 401 | 9
Mean (SD) | 26 (1) | 24 (1)
Median (Min, Max) | 26 (22 - 28) | 24 (23 - 25)
Postnatal Age at Start of Caffeine (days)
N | 401 | 9
Mean (SD) | 1 (4) | 0 (0)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 1)
Duration of Therapy (days)
N | 401 | 9
Mean (SD) | 61 (25) | 10 (10)
Median (Min, Max) | 60 (1 - 144) | 9 (2 - 33)
Gender
Female | 179 (96.8%) | 6 (3.2%)
Male | 222 (98.7%) | 3 (1.3%)
Birth Weight (grams)
N | 401 | 9
Mean (SD) | 818 (202) | 603 (164)
Median (Min, Max) | 810 (360 - 1460) | 595 (340 - 859)
Five Min Apgar Score
N | 397 | 9
Mean (SD) | 7 (2) | 6 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (2 - 8)
Cumulative Dose (mg/kg)^1^
N | 401 | 9
Mean (SD) | 483 (246) | 71 (65)
Median (Min, Max) | 459 (20 - 1231) | 52 (23 - 184)
Maximum Dose (mg/kg/day)^2^
N | 401 | 9
Mean (SD) | 22 (5) | 17 (6)
Median (Min, Max) | 20 (9 - 46) | 19 (5 - 22)
Most Current Dose (mg/kg/day)^3^
N | N/A | 9
Mean (SD) | N/A | 5 (1)
Median (Min, Max) | N/A | 5 (4 - 8)
Maximum Plasma Concentration (mg/L)^4^
N | 171 | 3
Mean (SD) | 25 (7) | 18 (9)
Median (Min, Max) | 25 (2 - 44) | 14 (12 - 29)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 3
Mean (SD) | N/A | 15 (2)
Median (Min, Max) | N/A | 14 (12 - 17)
31-50 | N/A | 0
<31 | N/A | 3

Note: Analyses include all caffeine doses received until the end of the event day.

* This refers to death prior to discharged or transferred from hospital.

1 Cumulative Dose-Participants With Event: cumulative dose from study start to the day of the event. Participants Without Event: the cumulative dose while on study caffeine.

2 Maximum Dose-Participants With Event: maximum daily dose up to the day of the event. Participants Without Event: maximum daily dose while on study caffeine.

3 Most Current Dose-Participants With Event: the daily dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.1.2.2 Dose Response Analysis of Clinical Events of Interest-BPD Safety Population

| Participants without BPD; (n=206) | Participants with BPD; (n=119)
Birth Gestation (weeks)
N | 206 | 119
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (23 - 28) | 25 (22 - 28)
Postnatal Age at Start of Caffeine (days)
N | 206 | 119
Mean (SD) | 1 (2) | 2 (6)
Median (Min, Max) | 0 (0 - 28) | 0 (0 - 44)
Duration of Therapy (days)
N | 206 | 119
Mean (SD) | 61 (16) | 67 (12)
Median (Min, Max) | 59 (29 - 118) | 67 (28 - 91)
Gender
Female | 87 (61.7%) | 54 (38.3%)
Male | 119 (64.7%) | 65 (35.3%)
Birth Weight (grams)
N | 206 | 119
Mean (SD) | 865 (174) | 722 (184)
Median (Min, Max) | 857 (460 - 1460) | 689 (370 - 1220)
Five Min Apgar Score
N | 205 | 116
Mean (SD) | 7 (2) | 7 (2)
Median (Min, Max) | 8 (1 - 9) | 7 (1 - 9)
Cumulative Dose (mg/kg)^1^
N | 206 | 119
Mean (SD) | 483 (187) | 523 (166)
Median (Min, Max) | 466 (161 - 1033) | 544 (207 - 863)
Maximum Dose (mg/kg/day)^2^
N | 206 | 119
Mean (SD) | 22 (5) | 21 (4)
Median (Min, Max) | 21 (9 - 46) | 20 (12 - 32)
Most Current Dose (mg/kg/day)^3^
N | N/A | 119
Mean (SD) | N/A | 7 (3)
Median (Min, Max) | N/A | 7 (2 - 20)
Maximum Plasma Concentration (mg/L)^4^
N | 90 | 47
Mean (SD) | 26 (6) | 25 (7)
Median (Min, Max) | 26 (7 - 44) | 25 (2 - 39)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 12
Mean (SD) | N/A | 9 (3)
Median (Min, Max) | N/A | 9 (3 - 15)
31-50 | N/A | 0
<31 | N/A | 12

Note: Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event: cumulative dose from study start to the day of the event. Participants Without Event: the cumulative dose while on study caffeine.

2 Maximum Dose-Participants With Event: maximum daily dose up to the day of the event. Participants Without Event: maximum daily dose while on study caffeine.

3 Most Current Dose-Participants With Event: the daily dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

6 Per protocol, all BPD events are included in this analysis. Per BPD definition, participants discharged from hospital before 36 weeks of PMA are excluded from this analysis.

Table 14.2.1.2.3 Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-Medical NEC Safety Population

| Participants without Medical NEC; (n=391) | Participants with Medical NEC; (n=19)
Birth Gestation (weeks)
N | 391 | 19
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (23 - 27)
Postnatal Age at Start of Caffeine (days)
N | 391 | 19
Mean (SD) | 1 (4) | 0 (1)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 2)
Duration of Therapy (days)
N | 391 | 19
Mean (SD) | 60 (25) | 31 (17)
Median (Min, Max) | 59 (1 - 144) | 32 (4 - 64)
Gender
Female | 177 (95.7%) | 8 (4.3%)
Male | 214 (95.1%) | 11 (4.9%)
Birth Weight (grams)
N | 391 | 19
Mean (SD) | 818 (204) | 721 (189)
Median (Min, Max) | 810 (340 - 1460) | 670 (430 - 1230)
Five Min Apgar Score
N | 387 | 19
Mean (SD) | 7 (2) | 7 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (2 - 9)
Cumulative Dose (mg/kg)^1^
N | 391 | 19
Mean (SD) | 474 (250) | 224 (135)
Median (Min, Max) | 458 (20 - 1231) | 211 (40 - 475)
Maximum Dose (mg/kg/day)^2^
N | 391 | 19
Mean (SD) | 21 (5) | 19 (5)
Median (Min, Max) | 20 (5 - 46) | 20 (12 - 27)
Most Current Dose (mg/kg/day)^3^
N | N/A | 19
Mean (SD) | N/A | 7 (2)
Median (Min, Max) | N/A | 7 (4 - 10)
Maximum Plasma Concentration (mg/L)^4^
N | 166 | 7
Mean (SD) | 25 (7) | 25 (4)
Median (Min, Max) | 25 (2 - 44) | 26 (19 - 29)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 5
Mean (SD) | N/A | 22 (7)
Median (Min, Max) | N/A | 24 (11 - 29)
31-50 | N/A | 0
<31 | N/A | 5

Note: Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event: cumulative dose from study start to the day of the event. Participants Without Event: the cumulative dose while on study caffeine.

2 Maximum Dose-Participants With Event: maximum daily dose up to the day of the event. Participants Without Event: maximum daily dose while on study caffeine.

3 Most Current Dose-Participants With Event: the daily dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.1.2.4 Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-Surgical NEC Safety Population

| Participants without Surgical NEC; (n=392) | Participants with Surgical NEC; (n=18)
Birth Gestation (weeks)
N | 392 | 18
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (23 - 27)
Postnatal Age at Start of Caffeine (days)
N | 392 | 18
Mean (SD) | 1 (4) | 1 (1)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 5)
Duration of Therapy (days)
N | 392 | 18
Mean (SD) | 61 (25) | 22 (15)
Median (Min, Max) | 60 (1 - 144) | 24 (4 - 50)
Gender
Female | 176 (95.1%) | 9 (4.9%)
Male | 216 (96.0%) | 9 (4.0%)
Birth Weight (grams)
N | 392 | 18
Mean (SD) | 819 (204) | 687 (149)
Median (Min, Max) | 810 (340 - 1460) | 720 (460 - 990)
Five Min Apgar Score
N | 388 | 18
Mean (SD) | 7 (2) | 7 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (2 - 9)
Cumulative Dose (mg/kg)^1^
N | 392 | 18
Mean (SD) | 478 (248) | 152 (91)
Median (Min, Max) | 458 (20 - 1231) | 145 (42 - 438)
Maximum Dose (mg/kg/day)^2^
N | 392 | 18
Mean (SD) | 21 (5) | 21 (4)
Median (Min, Max) | 20 (5 - 46) | 20 (12 - 31)
Most Current Dose (mg/kg/day)^3^
N | N/A | 18
Mean (SD) | N/A | 7 (3)
Median (Min, Max) | N/A | 7 (3 - 13)
Maximum Plasma Concentration (mg/L)^4^
N | 164 | 8
Mean (SD) | 25 (7) | 26 (5)
Median (Min, Max) | 25 (2 - 44) | 27 (17 - 34)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 8
Mean (SD) | N/A | 16 (3)
Median (Min, Max) | N/A | 17 (9 - 20)
31-50 | N/A | 0
<31 | N/A | 8

Note: Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event: cumulative dose from study start to the day of the event. Participants Without Event: the cumulative dose while on study caffeine.

2 Maximum Dose-Participants With Event: maximum daily dose up to the day of the event. Participants Without Event: maximum daily dose while on study caffeine.

3 Most Current Dose-Participants With Event: the daily dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.1.2.5 Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-Spontaneous Intestinal Perforation Safety Population

| Participants without Spontaneous Intestinal Perforation; (n=391) | Participants with Spontaneous Intestinal Perforation; (n=19)
Birth Gestation (weeks)
N | 391 | 19
Mean (SD) | 26 (1) | 24 (1)
Median (Min, Max) | 26 (22 - 28) | 24 (23 - 26)
Postnatal Age at Start of Caffeine (days)
N | 391 | 19
Mean (SD) | 1 (4) | 2 (4)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 17)
Duration of Therapy (days)
N | 391 | 19
Mean (SD) | 61 (25) | 7 (3)
Median (Min, Max) | 60 (1 - 144) | 6 (1 - 13)
Gender
Female | 175 (94.6%) | 10 (5.4%)
Male | 216 (96.0%) | 9 (4.0%)
Birth Weight (grams)
N | 391 | 19
Mean (SD) | 821 (203) | 663 (169)
Median (Min, Max) | 810 (340 - 1460) | 607 (425 - 961)
Five Min Apgar Score
N | 387 | 19
Mean (SD) | 7 (2) | 6 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (1 - 9)
Cumulative Dose (mg/kg)^1^
N | 391 | 19
Mean (SD) | 477 (244) | 62 (23)
Median (Min, Max) | 457 (20 - 1231) | 60 (28 - 120)
Maximum Dose (mg/kg/day)^2^
N | 391 | 19
Mean (SD) | 21 (5) | 21 (6)
Median (Min, Max) | 20 (5 - 46) | 20 (12 - 33)
Most Current Dose (mg/kg/day)^3^
N | N/A | 19
Mean (SD) | N/A | 9 (7)
Median (Min, Max) | N/A | 8 (4 - 32)
Maximum Plasma Concentration (mg/L)^4^
N | 170 | 2
Mean (SD) | 25 (7) | 17 (5)
Median (Min, Max) | 25 (2 - 44) | 17 (14 - 21)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 2
Mean (SD) | N/A | 17 (5)
Median (Min, Max) | N/A | 17 (14 - 21)
31-50 | N/A | 0
<31 | N/A | 2

Note: Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event: cumulative dose from study start to the day of the event. Participants Without Event: the cumulative dose while on study caffeine.

2 Maximum Dose-Participants With Event: maximum daily dose up to the day of the event. Participants Without Event: maximum daily dose while on study caffeine.

3 Most Current Dose-Participants With Event: the daily dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.1.2.6 Dose Response Analysis of Clinical Events of Interest-Grade II Intraventricular Hemorrhage Safety Population

| Participants without Grade II Intraventricular Hemorrhage; (n=381) | Participants with Grade II Intraventricular Hemorrhage; (n=29)
Birth Gestation (weeks)
N | 381 | 29
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (23 - 27)
Postnatal Age at Start of Caffeine (days)
N | 381 | 29
Mean (SD) | 1 (3) | 2 (8)
Median (Min, Max) | 0 (0 - 36) | 0 (0 - 44)
Duration of Therapy (days)
N | 381 | 27
Mean (SD) | 60 (25) | 6 (6)
Median (Min, Max) | 59 (1 - 144) | 5 (1 - 27)
Gender
Female | 169 (91.4%) | 16 (8.6%)
Male | 212 (94.2%) | 13 (5.8%)
Birth Weight (grams)
N | 381 | 29
Mean (SD) | 819 (202) | 739 (211)
Median (Min, Max) | 810 (340 - 1460) | 720 (370 - 1225)
Five Min Apgar Score
N | 378 | 28
Mean (SD) | 7 (2) | 6 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (1 - 9)
Cumulative Dose (mg/kg)^1^
N | 381 | 27
Mean (SD) | 472 (247) | 63 (59)
Median (Min, Max) | 455 (20 - 1231) | 49 (12 - 290)
Maximum Dose (mg/kg/day)^2^
N | 381 | 27
Mean (SD) | 21 (5) | 21 (4)
Median (Min, Max) | 20 (5 - 46) | 20 (12 - 28)
Most Current Dose (mg/kg/day)^3^
N | N/A | 27
Mean (SD) | N/A | 8 (4)
Median (Min, Max) | N/A | 8 (4 - 20)
Maximum Plasma Concentration (mg/L)^4^
N | 163 | 5
Mean (SD) | 25 (7) | 17 (6)
Median (Min, Max) | 25 (2 - 44) | 17 (11 - 24)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 6
Mean (SD) | N/A | 18 (6)
Median (Min, Max) | N/A | 18 (11 - 24)
31-50 | N/A | 0
<31 | N/A | 6

Note: Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event: cumulative dose from study start to the day of the event. Participants Without Event: the cumulative dose while on study caffeine.

2 Maximum Dose-Participants With Event: maximum daily dose up to the day of the event. Participants Without Event: maximum daily dose while on study caffeine.

3 Most Current Dose-Participants With Event: the daily dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.1.2.7 Dose Response Analysis of Clinical Events of Interest-Grade III or IV Intraventricular Hemorrhage Safety Population

| Participants without Grade III or IV Intraventricular Hemorrhage; (n=358) | Participants with Grade III or IV Intraventricular Hemorrhage; (n=52)
Birth Gestation (weeks)
N | 358 | 52
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (22 - 27)
Postnatal Age at Start of Caffeine (days)
N | 358 | 52
Mean (SD) | 1 (3) | 2 (7)
Median (Min, Max) | 0 (0 - 36) | 0 (0 - 44)
Duration of Therapy (days)
N | 358 | 47
Mean (SD) | 61 (24) | 7 (13)
Median (Min, Max) | 59 (1 - 144) | 3 (1 - 84)
Gender
Female | 159 (85.9%) | 26 (14.1%)
Male | 199 (88.4%) | 26 (11.6%)
Birth Weight (grams)
N | 358 | 52
Mean (SD) | 825 (203) | 738 (196)
Median (Min, Max) | 810 (340 - 1460) | 710 (370 - 1240)
Five Min Apgar Score
N | 355 | 51
Mean (SD) | 7 (2) | 6 (2)
Median (Min, Max) | 7 (1 - 9) | 6 (1 - 9)
Cumulative Dose (mg/kg)^1^
N | 358 | 47
Mean (SD) | 477 (241) | 72 (118)
Median (Min, Max) | 457 (20 - 1231) | 39 (15 - 741)
Maximum Dose (mg/kg/day)^2^
N | 358 | 47
Mean (SD) | 22 (5) | 20 (4)
Median (Min, Max) | 20 (5 - 46) | 20 (5 - 28)
Most Current Dose (mg/kg/day)^3^
N | N/A | 47
Mean (SD) | N/A | 10 (5)
Median (Min, Max) | N/A | 9 (4 - 25)
Maximum Plasma Concentration (mg/L)^4^
N | 152 | 6
Mean (SD) | 25 (7) | 19 (5)
Median (Min, Max) | 25 (2 - 44) | 19 (11 - 27)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 9
Mean (SD) | N/A | 18 (5)
Median (Min, Max) | N/A | 18 (11 - 24)
31-50 | N/A | 0
<31 | N/A | 9

Note: Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event: cumulative dose from study start to the day of the event. Participants Without Event: the cumulative dose while on study caffeine.

2 Maximum Dose-Participants With Event: maximum daily dose up to the day of the event. Participants Without Event: maximum daily dose while on study caffeine.

3 Most Current Dose-Participants With Event: the daily dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.1.2.8 Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-PDA Requiring Surgical Treatment Safety Population

| Participants without PDA Requiring Surgical Treatment; (n=360) | Participants with PDA Requiring Surgical Treatment; (n=50)
Birth Gestation (weeks)
N | 360 | 50
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (22 - 27)
Postnatal Age at Start of Caffeine (days)
N | 360 | 50
Mean (SD) | 1 (4) | 1 (1)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 9)
Duration of Therapy (days)
N | 360 | 50
Mean (SD) | 58 (26) | 21 (11)
Median (Min, Max) | 58 (1 - 144) | 20 (2 - 59)
Gender
Female | 161 (87.0%) | 24 (13.0%)
Male | 199 (88.4%) | 26 (11.6%)
Birth Weight (grams)
N | 360 | 50
Mean (SD) | 822 (209) | 752 (148)
Median (Min, Max) | 812 (340 - 1460) | 751 (430 - 1140)
Five Min Apgar Score
N | 357 | 49
Mean (SD) | 7 (2) | 7 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (1 - 9)
Cumulative Dose (mg/kg)^1^
N | 360 | 50
Mean (SD) | 462 (248) | 161 (92)
Median (Min, Max) | 453 (20 - 1231) | 144 (21 - 542)
Maximum Dose (mg/kg/day)^2^
N | 360 | 50
Mean (SD) | 21 (5) | 20 (6)
Median (Min, Max) | 20 (5 - 35) | 20 (10 - 32)
Most Current Dose (mg/kg/day)^3^
N | N/A | 50
Mean (SD) | N/A | 7 (2)
Median (Min, Max) | N/A | 7 (4 - 11)
Maximum Plasma Concentration (mg/L)^4^
N | 157 | 12
Mean (SD) | 25 (7) | 19 (7)
Median (Min, Max) | 25 (7 - 44) | 23 (2 - 26)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 10
Mean (SD) | N/A | 18 (5)
Median (Min, Max) | N/A | 19 (10 - 24)
31-50 | N/A | 0
<31 | N/A | 10

Note: Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event: cumulative dose from study start to the day of the event. Participants Without Event: the cumulative dose while on study caffeine.

2 Maximum Dose-Participants With Event: maximum daily dose up to the day of the event. Participants Without Event: maximum daily dose while on study caffeine.

3 Most Current Dose-Participants With Event: the daily dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.1.2.9 Dose Response Analysis of Clinical Events of Interest Attributed to Caffeine Exposure-Seizure Safety Population

| Participants without Seizure; (n=397) | Participants with Seizure; (n=13)
Birth Gestation (weeks)
N | 397 | 13
Mean (SD) | 26 (1) | 24 (1)
Median (Min, Max) | 26 (22 - 28) | 24 (23 - 27)
Postnatal Age at Start of Caffeine (days)
N | 397 | 13
Mean (SD) | 1 (4) | 0 (0)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 1)
Duration of Therapy (days)
N | 397 | 13
Mean (SD) | 61 (26) | 11 (12)
Median (Min, Max) | 60 (1 - 144) | 6 (1 - 46)
Gender
Female | 176 (95.1%) | 9 (4.9%)
Male | 221 (98.2%) | 4 (1.8%)
Birth Weight (grams)
N | 397 | 13
Mean (SD) | 817 (204) | 714 (160)
Median (Min, Max) | 810 (340 - 1460) | 720 (460 - 1060)
Five Min Apgar Score
N | 394 | 12
Mean (SD) | 7 (2) | 7 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (3 - 9)
Cumulative Dose (mg/kg)^1^
N | 397 | 13
Mean (SD) | 478 (251) | 85 (63)
Median (Min, Max) | 459 (20 - 1231) | 64 (13 - 204)
Maximum Dose (mg/kg/day)^2^
N | 397 | 13
Mean (SD) | 21 (5) | 21 (7)
Median (Min, Max) | 20 (5 - 46) | 22 (13 - 33)
Most Current Dose (mg/kg/day)^3^
N | N/A | 13
Mean (SD) | N/A | 10 (5)
Median (Min, Max) | N/A | 10 (4 - 22)
Maximum Plasma Concentration (mg/L)^4^
N | 171 | 0
Mean (SD) | 25 (7) | 0
Median (Min, Max) | 25 (2 - 44) | 0
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 1
Mean (SD) | N/A | 7
Median (Min, Max) | N/A | 7
31-50 | N/A | 0
<31 | N/A | 1

Note: Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event: cumulative dose from study start to the day of the event. Participants Without Event: the cumulative dose while on study caffeine.

2 Maximum Dose-Participants With Event: maximum daily dose up to the day of the event. Participants Without Event: maximum daily dose while on study caffeine.

3 Most Current Dose-Participants With Event: the daily dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.1.3.1.1 Study Dose As a Predictor of BPD Adjusted for Other Factors of Interest Safety Population

Factor | Odds Ratio | 95% CL | P-Value
Site-▬ (vs ▬) | 3.27 | (1.05, 10.51) | 0.04
Site-▬ (vs ▬) | 2.74 | (0.90, 8.63) | 0.08
Site-▬ (vs ▬) | 0.48 | (0.17, 1.30) | 0.15
Gestational Age (weeks) | 0.65 | (0.46, 0.92) | 0.02
Birth Weight^1^ (by units of 100 grams) | 0.68 | (0.55, 0.83) | <0.01
Mean Study Dose^2^ (mg/kg/day) | 0.91 | (0.75, 1.10) | 0.33
Duration of Therapy^3^ (day) | 0.96 | (0.94, 0.99) | <0.01
Cardiovascular Medication | 12.90 | (3.51, 72.76) | <0.01
Nervous System Medication | 0.68 | (0.33, 1.41) | 0.30
Systemic Anti-Infective Medication | 0.57 | (0.30, 1.09) | 0.09
Systemic Hormonal Medication | 2.90 | (1.38, 6.26) | <0.01
Alimentary/Metabolic Medication | 1.43 | (0.47, 4.38) | 0.53

Note: Analyses include all caffeine doses received until the end of the event day. Confidence limits are calculated via Profile Likelihood.

All BPD events are included in the analyses. Per BPD definition, participants discharged from hospital before 36 weeks of PMA are excluded from this analysis.

1 Every 100 grams birth weight increase will cause 32% decrease in the odds of getting BPD event.

2 Mean study dose-Participants With Event: Cumulative dose/dose days until the event day. Participants Without Event: Cumulative dose/dose days during the study period.

3 One day increase for the caffeine use without a BPD event will cause 4% decrease in the odds of getting a BPD event.

Table 14.2.1.3.1.2 Maximum Plasma Concentration As a Predictor of BPD Adjusted for Other Factors of Interest Safety Population

Factor | Odds Ratio | 95% CL | P-Value
Site-▬ (vs ▬) | 1.81 | (0.47, 7.21) | 0.39
Site-▬ (vs ▬) | 1.03 | (0.24, 4.38) | 0.96
Site-▬ (vs. ▬ | 0.15 | (0.01, 2.29) | 0.19
Gestational Age (weeks) | 0.55 | (0.29, 0.98) | 0.05
Birth Weight (by units of 100 grams) | 0.65 | (0.45, 0.92) | 0.02
Duration of Therapy (day) | 0.94 | (0.89, 0.99) | 0.02
Maximum Plasma Concentration^1^ (mg/L) | 0.96 | (0.90, 1.03) | 0.23
Cardiovascular Medication | 7.75 | (1.71, 56.53) | 0.02
Nervous System Medication | 1.49 | (0.51, 4.48) | 0.47
Systemic Anti-Infective Medication | 1.30 | (0.38, 4.48) | 0.68
Systemic Hormonal Medication | 2.67 | (0.71, 11.42) | 0.16
Alimentary/Metabolic Medication | 1.18 | (0.18, 7.40) | 0.86

Note: Analyses include all caffeine doses received until the end of the event day. Confidence limits are calculated via Profile Likelihood.

All BPD events are included in the analyses. Per BPD definition, participants discharged from hospital before 36 weeks of PMA are excluded from this analysis.

1 Maximum Plasma Concentration-Participants With Event: the maximum plasma concentration prior to the event. Participants Without Event: the maximum plasma concentration reported during the study period.

Table 14.2.1.3.1.3 Simulated Maximum Plasma Concentration As Predictor of BPD Adjusted for Other Factors of Interest Safety Population

Factor | Odds Ratio | 95% CL | P-Value
Site-▬ (vs. ▬ | 3.56 | (1.26, 10.40) | 0.02
Site-▬ (vs. ▬ | 2.99 | (1.03, 8.94) | 0.05
Site-▬ (vs. ▬ | 0.44 | (0.17, 1.14) | 0.10
Gestational Age (weeks) | 0.64 | (0.44, 0.90) | 0.01
Birth Weight^1^ (by units of 100 grams) | 0.70 | (0.56, 0.85) | <0.01
Duration of Therapy^2^ (day) | 0.96 | (0.94, 0.99) | 0.01
Maximum Plasma Concentration^3^ (mg/L) | 0.98 | (0.96, 1.00) | 0.11
Cardiovascular Medication | 13.06 | (3.51, 76.04) | <0.01
Nervous System Medication | 0.67 | (0.32, 1.39) | 0.28
Systemic Anti-Infective Medication | 0.57 | (0.30, 1.07) | 0.08
Systemic Hormonal Medication | 2.78 | (1.32, 6.04) | <0.01
Alimentary/Metabolic Medication | 1.38 | (0.45, 4.26) | 0.57

Note: Analyses include all caffeine doses received until the end of the event day. Confidence limits are calculated via Profile Likelihood.

All BPD events are included in the analyses. Per BPD definition, participants discharged from hospital before 36 weeks of PMA are excluded from this analysis.

1 Every 100 grams birth weight increase will cause 30% decrease in the odds of getting BPD event.

2 One day increase for the caffeine use without a BPD event will cause 4% decrease in the odds of getting a BPD event.

3 Maximum Plasma Concentration-Participants With Event: the maximum plasma concentration prior to the event. Participants Without Event: the maximum plasma concentration reported during the study period.

Table 14.2.1.3.2.1 Study Dose As a Predictor of NEC Adjusted for Other Factors of Interest Safety Population

Factor | Odds Ratio | 95% CL | P-Value
Site-▬ (vs. ▬ | 0.59 | (0.14, 2.58) | 0.47
Site-▬ (vs. ▬ | 0.28 | (0.05, 1.41) | 0.12
Site-▬ (vs. ▬ | 0.89 | (0.19, 4.30) | 0.89
Gestational Age (weeks) | 1.19 | (0.74, 1.91) | 0.47
Birth Weight^1^ (by units of 100 grams) | 0.72 | (0.53, 0.98) | 0.04
Mean Study Dose^2,^ ^3^ (mg/kg/day) | 0.78 | (0.63, 0.92) | <0.01
Duration of Therapy^4^ (day) | 0.93 | (0.91, 0.96) | <0.0001
Cardiovascular Medication | 0.61 | (0.21, 1.83) | 0.38
Nervous System Medication | 1.00 | (0.34, 2.99) | 1.00
Systemic Anti-Infective | 1.10 | (0.42, 3.00) | 0.84
Systemic Hormonal Medication | 1.27 | (0.41, 3.65) | 0.67

Note: Analyses include all caffeine doses received until the end of the event day. Confidence limits are calculated via Profile Likelihood.

NEC events include either Medical or Surgical NEC events.

1 Every 100 grams birth weight increase will cause 28% decrease in the odds of getting BPD event.

2 Mean study dose-Participants With Event: Cumulative dose/dose days until the event day. Participants Without Event: Cumulative dose/dose days during the study period.

3 One mg/kg increase for the daily dose will cause 22% decrease in the odds of getting NEC event.

4 One day increase for the caffeine use without an NEC event will cause 7% decrease in the odds of getting an NEC event.

All participants with NEC events had no Alimentary/Metabolic Medications reported.

Table 14.2.1.3.2.2 Most Current Plasma Concentration As a Predictor of NEC Adjusted for Other Factors of Interest Safety Population

Factor | Odds Ratio | 95% CL | P-Value
Gestational Age (weeks) | 1.70 | (0.74, 4.19) | 0.22
Birth Weight (by units of 100 grams) | 0.38 | (0.17, 0.72) | <0.01
Duration of Therapy (day) | 0.94 | (0.91, 0.97) | <0.01
Most Current Plasma Concentration^1^ (mg/L) | 1.10 | (0.99, 1.23) | 0.07
Cardiovascular Medication | 0.33 | (0.03, 2.97) | 0.33
Nervous System Medication | 1.74 | (0.25, 13.44) | 0.58
Systemic Anti-Infective | 0.37 | (0.05, 2.37) | 0.31
Systemic Hormonal Medication | 4.20 | (0.44, 38.90) | 0.20

Note: Analyses include all caffeine doses received until the end of the event day. Confidence limits are calculated via Profile Likelihood.

NEC events include either Medical or Surgical NEC events.

1 Most Current Plasma Concentration-Participants With Event: the measure of plasma concentration recorded closest to the time of the event (within 7 days). Participants Without Event: the last plasma concentration reported during the study period.

All participants with NEC events had no Alimentary/Metabolic Medications reported.

Table 14.2.1.3.2.3 Simulated Current Plasma Concentration As Predictor of NEC Adjusted for Other Factors of Interest Safety Population

Factor | Odds Ratio | 95% CL | P-Value
Site-▬ (vs. ▬ | 1.01 | (0.29, 3.91) | 0.99
Site-▬ (vs. ▬ | 0.72 | (0.15, 3.48) | 0.67
Site-▬ (vs. ▬ | 0.92 | (0.20, 4.16) | 0.91
Gestational Age (weeks) | 1.26 | (0.79, 1.99) | 0.32
Birth Weight^1^ (by units of 100 grams) | 0.69 | (0.51, 0.93) | 0.02
Duration of Therapy^2^ (day) | 0.95 | (0.93, 0.97) | <0.0001
Most Current Plasma Concentration^3^ (mg/L) | 1.01 | (0.97, 1.06) | 0.54
Cardiovascular Medication | 0.72 | (0.26, 2.05) | 0.53
Nervous System Medication | 0.91 | (0.33, 2.59) | 0.86
Systemic Anti-Infective | 0.87 | (0.33, 2.28) | 0.77
Systemic Hormonal Medication | 1.07 | (0.36, 2.99) | 0.89

Note: Analyses include all caffeine doses received until the end of the event day. Confidence limits are calculated via Profile Likelihood.

NEC events include either Medical or Surgical NEC events.

1 Every 100 grams birth weight increase will cause 31% decrease in the odds of getting BPD event.

2 One day increase for the caffeine use without an NEC event will cause 5% decrease in the odds of getting an NEC event.

3 Most Current Plasma Concentration-Participants With Event: the measure of plasma concentration recorded closest to the time of the event (within 7 days). Participants Without Event: the last plasma concentration reported during the study period.

All participants with NEC events had no Alimentary/Metabolic Medications reported.

Table 14.2.1.3.3.1 Study Dose As a Predictor of PDA Adjusted for Other Factors of Interest Safety Population

Factor | Odds Ratio | 95% CL | P-Value
Mean Study Dose^1,2^ (mg/kg/day) | 0.87 | (0.78, 0.97) | 0.01
Site-▬ (vs. ▬ | 5.35 | (1.16, 29.26) | 0.04
Site-▬ (vs. ▬ | 2.25 | (0.68, 7.65) | 0.19
Site-▬ (vs. ▬ | 0.68 | (0.19, 2.36) | 0.55
Gestational Age (weeks) | 1.12 | (0.72, 1.79) | 0.62
Birth Weight (by units of 100 grams) | 1.01 | (0.75, 1.36) | 0.94
Duration of Therapy^3^ (days) | 0.85 | (0.81, 0.88) | <0.0001
Nervous System Medication (yes vs no) | 0.81 | (0.31, 2.11) | 0.66
Systemic Anti-Infective (yes vs no) | 1.09 | (0.42, 2.84) | 0.86
Systemic Hormonal Medication (yes vs no) | 0.17 | (0.04, 0.62) | <0.01

Note: Analyses include all caffeine doses received until the end of the event day. Model includes all variables listed above. Confidence limits are calculated via Profile Likelihood.

Participants used Ibuprofen or Indomethacin as concomitant medication are considered to have PDA requiring medical treatment. Doses of both medications given on birth date and next day are excluded.

The overall site level p-value is 0.0295.

1 Mean study dose-Participants With Event: Cumulative dose/dose days until the event day. Participants Without Event: Cumulative dose/dose days during the study period.

2 One mg/kg increase for the daily dose will cause 13% decrease in the odds of getting PDA event.

3 One day increase for the caffeine use without a PDA event will cause 15% decrease in the odds of getting a PDA event.

Table 14.2.1.3.3.2 Most Current Plasma Concentration As a Predictor of PDA Adjusted for Other Factors of Interest Safety Population

Factor | Odds Ratio | 95% CL | P-Value
Most Current Plasma Concentration^1^ (mg/L) | 1.39 | (1.06, 2.27) | 0.07
Gestational Age (weeks) | 0.09 | (0, 0.47) | 0.02
Birth Weight (by units of 100 grams) | 1.90 | (0.85, 6.04) | 0.17
Duration of Therapy (days) | 0.78 | (0.63, 0.87) | <0.01
Nervous System Medication (yes vs no) | 1.29 | (0.05, 59.21) | 0.88
Systemic Anti-Infective Medication (yes vs no) | 0.05 | (0, 2.39) | 0.16

Note: Analyses include all caffeine doses received until the end of the event day. Model includes all variables listed above. Confidence limits are calculated via Profile Likelihood.

Participants used Ibuprofen or Indomethacin as concomitant medication are considered to have PDA requiring medical treatment. Doses of both medications given on birth date and next day are excluded.

1 Most Current Plasma Concentration-Participants With Event: the measure of plasma concentration recorded closest to the time of the event (within 7 days). Participants Without Event: the last plasma concentration reported during the study period.

All participants with PDA events and most current plasma concentration reported had cadiovascular concomitant medications and no systemic hormonal medications reported.

Table 14.2.1.3.3.3 Simulated Current Plasma Concentration As Predictor of PDA Adjusted for Other Factors of Interest Safety Population

Factor | Odds Ratio | 95% CL | P-Value
Most Current Plasma Concentration^1^ (mg/L) | 1.05 | (1.01, 1.09) | 0.01
Site-▬ (vs. ▬ | 4.37 | (0.94, 24.15) | 0.07
Site-▬ (vs. ▬ | 3.02 | (0.93, 10.22) | 0.07
Site-▬ (vs. ▬ | 1.35 | (0.38, 4.83) | 0.64
Gestational Age (weeks) | 1.16 | (0.75, 1.83) | 0.51
Birth Weight (by units of 100 grams) | 0.92 | (0.69, 1.22) | 0.57
Duration of Therapy^2^ (days) | 0.87 | (0.84, 0.90) | <0.0001
Nervous System Medication (yes vs no) | 0.79 | (0.31, 2.05) | 0.63
Systemic Anti-Infective (yes vs no) | 0.60 | (0.22, 1.62) | 0.31
Systemic Hormonal Medication (yes vs no) | 0.23 | (0.06, 0.87) | 0.03

Note: Analyses include all caffeine doses received until the end of the event day. Model includes all variables listed above. Confidence limits are calculated via Profile Likelihood.

Participants used Ibuprofen or Indomethacin as concomitant medication are considered to have PDA requiring medical treatment. Doses of both medications given on birth date and next day are excluded.

1 Most Current Plasma Concentration-Participants With Event: measure of plasma concentration recorded on event day. Participants Without Event: the last plasma concentration reported during the study period.

2 One day increase for the caffeine use without a PDA event will cause 13% decrease in the odds of getting a PDA event.

Table 14.2.2.1.1 Summary of Laboratory Events of Interest Attributed to Caffeine Exposure by Site and Severity Safety Population

| ▬; (N=100) | | ▬; (N=108) | | ▬; (N=107) | | ▬; (N=95) | | Total; (N=410)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Hyperglycemia
Number of Events | 365 | 0 | 369 | 3 | 1099 | 15 | 1306 | 10 | 3139 | 28
Events per Day^1^ | 0.047 | 0 | 0.065 | 0.001 | 0.209 | 0.003 | 0.220 | 0.002 | 0.127 | 0.001
Number of Participants | 60 (60.0%) | 0 | 72 (66.7%) | 3 (2.8%) | 90 (84.1%) | 3 (2.8%) | 79 (83.2%) | 5 (5.3%) | 301 (73.4%) | 11 (2.7%)
Hypoglycemia
Number of Events | 26 | 1 | 26 | 5 | 105 | 7 | 74 | 7 | 231 | 20
Events per Day^1^ | 0.003 | 0 | 0.005 | 0.001 | 0.020 | 0.001 | 0.012 | 0.001 | 0.009 | 0.001
Number of Participants | 15 (15.0%) | 1 (1.0%) | 20 (18.5%) | 5 (4.6%) | 41 (38.3%) | 7 (6.5%) | 34 (35.8%) | 6 (6.3%) | 110 (26.8%) | 19 (4.6%)
Hypernatremia
Number of Events | 20 | 1 | 68 | 6 | 56 | 1 | 68 | 1 | 212 | 9
Events per Day^1^ | 0.003 | 0 | 0.012 | 0.001 | 0.011 | 0 | 0.011 | 0 | 0.009 | 0
Number of Participants | 8 (8.0%) | 1 (1.0%) | 38 (35.2%) | 1 (0.9%) | 20 (18.7%) | 1 (0.9%) | 30 (31.6%) | 1 (1.1%) | 96 (23.4%) | 4 (1.0%)
Hyponatremia
Number of Events | 37 | 0 | 44 | 3 | 5 | 0 | 16 | 0 | 102 | 3
Events per Day^1^ | 0.005 | 0 | 0.008 | 0.001 | 0.001 | 0 | 0.003 | 0 | 0.004 | 0
Number of Participants | 16 (16.0%) | 0 | 25 (23.1%) | 3 (2.8%) | 3 (2.8%) | 0 | 8 (8.4%) | 0 | 52 (12.7%) | 3 (0.7%)
Hypercalcemia
Number of Events | 0 | 0 | 5 | 0 | 0 | 0 | 2 | 0 | 7 | 0
Events per Day^1^ | 0 | 0 | 0.001 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 4 (3.7%) | 0 | 0 | 0 | 2 (2.1%) | 0 | 6 (1.5%) | 0
Hypocalcemia
Number of Events | 226 | 14 | 2 | 0 | 1 | 0 | 6 | 0 | 235 | 14
Events per Day^1^ | 0.029 | 0.002 | 0 | 0 | 0 | 0 | 0.001 | 0 | 0.010 | 0.001
Number of Participants | 66 (66.0%) | 12 (12.0%) | 2 (1.9%) | 0 | 1 (0.9%) | 0 | 5 (5.3%) | 0 | 74 (18.0%) | 12 (2.9%)
Elevated Creatinine
Number of Events | 5 | 13 | 57 | 0 | 15 | 0 | 6 | 0 | 83 | 13
Events per Day^1^ | 0.001 | 0.002 | 0.010 | 0 | 0.003 | 0 | 0.001 | 0 | 0.003 | 0.001
Number of Participants | 3 (3.0%) | 1 (1.0%) | 17 (15.7%) | 0 | 6 (5.6%) | 0 | 2 (2.1%) | 0 | 28 (6.8%) | 1 (0.2%)
Elevated ALT
Number of Events | 0 | 0 | 2 | 0 | 0 | 0 | 0 | 0 | 2 | 0
Events per Day^1^ | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 1 (0.9%) | 0 | 0 | 0 | 0 | 0 | 1 (0.2%) | 0
Elevated AST
Number of Events | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 0
Events per Day^1^ | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Number of Participants | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.1%) | 0 | 1 (0.2%) | 0

Note: Laboratory events of interest are attributed to caffeine if it is presented on a day that the participant was exposed to caffeine.

Only laboratory events of interest that occurred on a day of caffeine dosing are included.

1 Events per day is calculated using the total number of events and day on caffeine dosing across all participants.

Table 14.2.2.1.2 Summary of Classification for Laboratory Events of Interest Attributed to Caffeine Exposure by Site and Severity Safety Population

| ▬; (N=100) | | ▬; (N=108) | | ▬; (N=107) | | ▬; (N=95) | | Total; (N=410)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Serum Electrolytes
Number of Events | 674 | 16 | 514 | 17 | 1266 | 23 | 1472 | 18 | 3926 | 74
Number of Participants | 86 (86.0%) | 14 (14.0%) | 83 (76.9%) | 11 (10.2%) | 97 (90.7%) | 10 (9.3%) | 86 (90.5%) | 9 (9.5%) | 352 (85.9%) | 44 (10.7%)
Renal Dysfunction
Number of Events | 5 | 13 | 57 | 0 | 15 | 0 | 6 | 0 | 83 | 13
Number of Participants | 3 (3.0%) | 1 (1.0%) | 17 (15.7%) | 0 | 6 (5.6%) | 0 | 2 (2.1%) | 0 | 28 (6.8%) | 1 (0.2%)
Liver Dysfunction
Number of Events | 0 | 0 | 2 | 0 | 0 | 0 | 1 | 0 | 3 | 0
Number of Participants | 0 | 0 | 1 (0.9%) | 0 | 0 | 0 | 1 (1.1%) | 0 | 2 (0.5%) | 0

Note: Laboratory events of interest are attributed to caffeine if it is presented on a day that the participant was exposed to caffeine.

Only laboratory events of interest that occurred on a day of caffeine dosing are included.

Table 14.2.2.2.1 Dose Response Analysis of Laboratory Events of Interest Attributed to Caffeine Exposure-Hyperglycemia Safety Population

| Participants without Hyperglycemia; (n=108) | Participants with Hyperglycemia; (n=302)
Birth Gestation (weeks)
N | 108 | 302
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (22 - 28)
Postnatal Age (days) at Start of Caffeine
N | 108 | 302
Mean (SD) | 1 (6) | 1 (3)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 28)
Duration of Therapy (days)
N | 108 | 302
Mean (SD) | 59 (20) | 7 (13)
Median (Min, Max) | 59 (1 - 109) | 3 (1 - 127)
Gender
Female | 48 (25.9%) | 137 (74.1%)
Male | 60 (26.7%) | 165 (73.3%)
Birth Weight (grams)
N | 108 | 302
Mean (SD) | 902 (206) | 782 (194)
Median (Min, Max) | 900 (370 - 1460) | 770 (340 - 1360)
Five Min Apgar Score
N | 108 | 298
Mean (SD) | 7 (2) | 7 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (1 - 9)
Cumulative Dose (mg/kg)^1^
N | 108 | 302
Mean (SD) | 488 (222) | 66 (103)
Median (Min, Max) | 488 (20 - 991) | 33 (2 - 1156)
Maximum Dose (mg/kg/day)^2^
N | 108 | 302
Mean (SD) | 21 (5) | 21 (5)
Median (Min, Max) | 20 (9 - 35) | 20 (2 - 33)
Most Current Dose (mg/kg/day)^3^
N | N/A | 302
Mean (SD) | N/A | 11 (7)
Median (Min, Max) | N/A | 9 (2 - 33)
Maximum Plasma Concentration (mg/L)^4^
N | 37 | 48
Mean (SD) | 28 (6) | 22 (8)
Median (Min, Max) | 28 (15 - 41) | 23 (2 - 39)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 80
Mean (SD) | N/A | 19 (6)
Median (Min, Max) | N/A | 18 (8 - 36)
31-50 | N/A | 2
<31 | N/A | 78

Note: If a lab event occurs multiple times at different severity levels while on caffeine, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative caffeine dose from study start to the day of the event. Participants Without Event: the cumulative dose while on caffeine.

2 Maximum Dose-Participants With Event: maximum daily caffeine dose up to the day of the event. Participants Without Event: maximum daily dose while on caffeine.

3 Most Current Dose-Participants With Event: the daily caffeine dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.2.2.2 Dose Response Analysis of Laboratory Events of Interest Attributed to Caffeine Exposure-Hypoglycemia Safety Population

| Participants without Hypoglycemia; (n=293) | Participants with Hypoglycemia; (n=117)
Birth Gestation (weeks)
N | 293 | 117
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (22 - 28)
Postnatal Age (days) at Start of Caffeine
N | 293 | 117
Mean (SD) | 1 (4) | 1 (2)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 17)
Duration of Therapy (days)
N | 293 | 117
Mean (SD) | 61 (24) | 12 (15)
Median (Min, Max) | 60 (1 - 144) | 4 (1 - 55)
Gender
Female | 125 (67.6%) | 60 (32.4%)
Male | 168 (74.7%) | 57 (25.3%)
Birth Weight (grams)
N | 293 | 117
Mean (SD) | 838 (195) | 751 (214)
Median (Min, Max) | 820 (360 - 1460) | 750 (340 - 1390)
Five Min Apgar Score
N | 289 | 117
Mean (SD) | 7 (2) | 7 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (1 - 9)
Cumulative Dose (mg/kg)^1^
N | 293 | 117
Mean (SD) | 481 (239) | 106 (123)
Median (Min, Max) | 460 (20 - 1231) | 35 (13 - 625)
Maximum Dose (mg/kg/day)^2^
N | 293 | 117
Mean (SD) | 21 (5) | 21 (4)
Median (Min, Max) | 20 (9 - 46) | 20 (5 - 35)
Most Current Dose (mg/kg/day)^3^
N | N/A | 117
Mean (SD) | N/A | 14 (8)
Median (Min, Max) | N/A | 10 (4 - 35)
Maximum Plasma Concentration (mg/L)^4^
N | 108 | 24
Mean (SD) | 26 (7) | 24 (8)
Median (Min, Max) | 26 (2 - 44) | 25 (9 - 39)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 45
Mean (SD) | N/A | 18 (6)
Median (Min, Max) | N/A | 17 (7 - 36)
31-50 | N/A | 1
<31 | N/A | 44

Note: If a lab event occurs multiple times at different severity levels while on caffeine, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative caffeine dose from study start to the day of the event. Participants Without Event: the cumulative dose while on caffeine.

2 Maximum Dose-Participants With Event: maximum daily caffeine dose up to the day of the event. Participants Without Event: maximum daily dose while on caffeine.

3 Most Current Dose-Participants With Event: the daily caffeine dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.2.2.3 Dose Response Analysis of Laboratory Events of Interest Attributed to Caffeine Exposure-Hypernatremia Safety Population

| Participants without Hypernatremia; (n=314) | Participants with Hypernatremia; (n=96)
Birth Gestation (weeks)
N | 314 | 96
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (22 - 28)
Postnatal Age (days) at Start of Caffeine
N | 314 | 96
Mean (SD) | 1 (4) | 1 (2)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 17)
Duration of Therapy (days)
N | 314 | 96
Mean (SD) | 61 (26) | 4 (6)
Median (Min, Max) | 59 (1 - 144) | 2 (1 - 40)
Gender
Female | 137 (74.1%) | 48 (25.9%)
Male | 177 (78.7%) | 48 (21.3%)
Birth Weight (grams)
N | 314 | 96
Mean (SD) | 837 (199) | 736 (201)
Median (Min, Max) | 820 (370 - 1460) | 710 (340 - 1230)
Five Min Apgar Score
N | 313 | 93
Mean (SD) | 7 (2) | 7 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (1 - 9)
Cumulative Dose (mg/kg)^1^
N | 314 | 96
Mean (SD) | 484 (253) | 40 (37)
Median (Min, Max) | 472 (20 - 1231) | 29 (2 - 238)
Maximum Dose (mg/kg/day)^2^
N | 314 | 96
Mean (SD) | 22 (5) | 19 (5)
Median (Min, Max) | 21 (9 - 46) | 20 (2 - 33)
Most Current Dose (mg/kg/day)^3^
N | N/A | 96
Mean (SD) | N/A | 9 (6)
Median (Min, Max) | N/A | 8 (2 - 30)
Maximum Plasma Concentration (mg/L)^4^
N | 143 | 2
Mean (SD) | 25 (7) | 29 (1)
Median (Min, Max) | 25 (2 - 44) | 29 (28 - 30)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 15
Mean (SD) | N/A | 17 (5)
Median (Min, Max) | N/A | 15 (8 - 28)
31-50 | N/A | 0
<31 | N/A | 15

Note: If a lab event occurs multiple times at different severity levels while on caffeine, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative caffeine dose from study start to the day of the event. Participants Without Event: the cumulative dose while on caffeine.

2 Maximum Dose-Participants With Event: maximum daily caffeine dose up to the day of the event. Participants Without Event: maximum daily dose while on caffeine.

3 Most Current Dose-Participants With Event: the daily caffeine dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.2.2.4 Dose Response Analysis of Laboratory Events of Interest Attributed to Caffeine Exposure-Hyponatremia Safety Population

| Participants without Hyponatremia; (n=357) | Participants with Hyponatremia; (n=53)
Birth Gestation (weeks)
N | 357 | 53
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (22 - 27)
Postnatal Age (days) at Start of Caffeine
N | 357 | 53
Mean (SD) | 1 (3) | 1 (5)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 36)
Duration of Therapy (days)
N | 357 | 53
Mean (SD) | 60 (25) | 16 (16)
Median (Min, Max) | 58 (1 - 133) | 11 (1 - 70)
Gender
Female | 157 (84.9%) | 28 (15.1%)
Male | 200 (88.9%) | 25 (11.1%)
Birth Weight (grams)
N | 357 | 53
Mean (SD) | 824 (207) | 741 (168)
Median (Min, Max) | 810 (340 - 1460) | 750 (420 - 1170)
Five Min Apgar Score
N | 354 | 52
Mean (SD) | 7 (2) | 6 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (1 - 9)
Cumulative Dose (mg/kg)^1^
N | 357 | 53
Mean (SD) | 472 (250) | 120 (93)
Median (Min, Max) | 456 (20 - 1211) | 96 (16 - 340)
Maximum Dose (mg/kg/day)^2^
N | 357 | 53
Mean (SD) | 22 (5) | 19 (5)
Median (Min, Max) | 20 (5 - 46) | 20 (10 - 33)
Most Current Dose (mg/kg/day)^3^
N | N/A | 53
Mean (SD) | N/A | 9 (5)
Median (Min, Max) | N/A | 8 (4 - 25)
Maximum Plasma Concentration (mg/L)^4^
N | 164 | 5
Mean (SD) | 25 (7) | 20 (8)
Median (Min, Max) | 25 (2 - 44) | 21 (10 - 29)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 6
Mean (SD) | N/A | 17 (7)
Median (Min, Max) | N/A | 15 (10 - 29)
31-50 | N/A | 0
<31 | N/A | 6

Note: If a lab event occurs multiple times at different severity levels while on caffeine, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative caffeine dose from study start to the day of the event. Participants Without Event: the cumulative dose while on caffeine.

2 Maximum Dose-Participants With Event: maximum daily caffeine dose up to the day of the event. Participants Without Event: maximum daily dose while on caffeine.

3 Most Current Dose-Participants With Event: the daily caffeine dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.2.2.5 Dose Response Analysis of Laboratory Events of Interest Attributed to Caffeine Exposure-Hypercalcemia Safety Population

| Participants without Hypercalcemia; (n=404) | Participants with Hypercalcemia; (n=6)
Birth Gestation (weeks)
N | 404 | 6
Mean (SD) | 26 (1) | 25 (2)
Median (Min, Max) | 26 (22 - 28) | 25 (22 - 27)
Postnatal Age (days) at Start of Caffeine
N | 404 | 6
Mean (SD) | 1 (4) | 0 (0)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 1)
Duration of Therapy (days)
N | 404 | 6
Mean (SD) | 60 (26) | 9 (5)
Median (Min, Max) | 59 (1 - 144) | 10 (4 - 14)
Gender
Female | 182 (98.4%) | 3 (1.6%)
Male | 222 (98.7%) | 3 (1.3%)
Birth Weight (grams)
N | 404 | 6
Mean (SD) | 814 (204) | 767 (189)
Median (Min, Max) | 800 (340 - 1460) | 725 (580 - 1075)
Five Min Apgar Score
N | 400 | 6
Mean (SD) | 7 (2) | 6 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (4 - 8)
Cumulative Dose (mg/kg)^1^
N | 404 | 6
Mean (SD) | 475 (252) | 55 (15)
Median (Min, Max) | 457 (20 - 1231) | 59 (32 - 69)
Maximum Dose (mg/kg/day)^2^
N | 404 | 6
Mean (SD) | 22 (5) | 15 (6)
Median (Min, Max) | 20 (5 - 46) | 15 (5 - 20)
Most Current Dose (mg/kg/day)^3^
N | N/A | 6
Mean (SD) | N/A | 6 (1)
Median (Min, Max) | N/A | 5 (4 - 8)
Maximum Plasma Concentration (mg/L)^4^
N | 173 | 0
Mean (SD) | 25 (7)
Median (Min, Max) | 25 (2 - 44)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 0
Mean (SD) | N/A
Median (Min, Max) | N/A
31-50 | N/A | 0
<31 | N/A | 0

Note: If a lab event occurs multiple times at different severity levels while on caffeine, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative caffeine dose from study start to the day of the event. Participants Without Event: the cumulative dose while on caffeine.

2 Maximum Dose-Participants With Event: maximum daily caffeine dose up to the day of the event. Participants Without Event: maximum daily dose while on caffeine.

3 Most Current Dose-Participants With Event: the daily caffeine dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.2.2.6 Dose Response Analysis of Laboratory Events of Interest Attributed to Caffeine Exposure-Hypocalcemia Safety Population

| Participants without Hypocalcemia; (n=333) | Participants with Hypocalcemia; (n=77)
Birth Gestation (weeks)
N | 333 | 77
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (23 - 27)
Postnatal Age (days) at Start of Caffeine
N | 333 | 77
Mean (SD) | 1 (3) | 2 (5)
Median (Min, Max) | 0 (0 - 44) | 1 (0 - 36)
Duration of Therapy (days)
N | 333 | 77
Mean (SD) | 56 (24) | 15 (18)
Median (Min, Max) | 56 (1 - 130) | 5 (1 - 79)
Gender
Female | 152 (82.2%) | 33 (17.8%)
Male | 181 (80.4%) | 44 (19.6%)
Birth Weight (grams)
N | 333 | 77
Mean (SD) | 816 (207) | 801 (191)
Median (Min, Max) | 800 (340 - 1460) | 800 (420 - 1195)
Five Min Apgar Score
N | 331 | 75
Mean (SD) | 7 (2) | 6 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (1 - 9)
Cumulative Dose (mg/kg)^1^
N | 333 | 77
Mean (SD) | 425 (229) | 153 (163)
Median (Min, Max) | 403 (20 - 1129) | 64 (19 - 725)
Maximum Dose (mg/kg/day)^2^
N | 333 | 77
Mean (SD) | 21 (5) | 21 (3)
Median (Min, Max) | 20 (5 - 46) | 20 (11 - 31)
Most Current Dose (mg/kg/day)^3^
N | N/A | 77
Mean (SD) | N/A | 10 (4)
Median (Min, Max) | N/A | 10 (5 - 27)
Maximum Plasma Concentration (mg/L)^4^
N | 152 | 6
Mean (SD) | 25 (6) | 32 (7)
Median (Min, Max) | 25 (7 - 44) | 34 (20 - 39)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 7
Mean (SD) | N/A | 21 (11)
Median (Min, Max) | N/A | 25 (2 - 32)
31-50 | N/A | 1
<31 | N/A | 6

Note: If a lab event occurs multiple times at different severity levels while on caffeine, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative caffeine dose from study start to the day of the event. Participants Without Event: the cumulative dose while on caffeine.

2 Maximum Dose-Participants With Event: maximum daily caffeine dose up to the day of the event. Participants Without Event: maximum daily dose while on caffeine.

3 Most Current Dose-Participants With Event: the daily caffeine dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.2.2.2.7 Dose Response Analysis of Laboratory Events of Interest Attributed to Caffeine Exposure-Elevated Creatinine Safety Population

| Participants without Elevated Creatinine; (n=382) | Participants with Elevated Creatinine; (n=28)
Birth Gestation (weeks)
N | 382 | 28
Mean (SD) | 26 (1) | 25 (1)
Median (Min, Max) | 26 (22 - 28) | 25 (23 - 27)
Postnatal Age (days) at Start of Caffeine
N | 382 | 28
Mean (SD) | 1 (4) | 0 (1)
Median (Min, Max) | 0 (0 - 44) | 0 (0 - 4)
Duration of Therapy (days)
N | 382 | 28
Mean (SD) | 61 (25) | 13 (10)
Median (Min, Max) | 59 (1 - 144) | 11 (1 - 33)
Gender
Female | 174 (94.1%) | 11 (5.9%)
Male | 208 (92.4%) | 17 (7.6%)
Birth Weight (grams)
N | 382 | 28
Mean (SD) | 824 (203) | 673 (157)
Median (Min, Max) | 810 (340 - 1460) | 670 (425 - 1170)
Five Min Apgar Score
N | 378 | 28
Mean (SD) | 7 (2) | 7 (2)
Median (Min, Max) | 7 (1 - 9) | 7 (2 - 9)
Cumulative Dose (mg/kg)^1^
N | 382 | 28
Mean (SD) | 477 (250) | 116 (91)
Median (Min, Max) | 458 (20 - 1231) | 78 (25 - 340)
Maximum Dose (mg/kg/day)^2^
N | 382 | 28
Mean (SD) | 21 (5) | 20 (6)
Median (Min, Max) | 20 (5 - 46) | 20 (5 - 33)
Most Current Dose (mg/kg/day)^3^
N | N/A | 28
Mean (SD) | N/A | 8 (4)
Median (Min, Max) | N/A | 8 (4 - 25)
Maximum Plasma Concentration (mg/L)^4^
N | 168 | 4
Mean (SD) | 25 (7) | 13 (6)
Median (Min, Max) | 25 (2 - 44) | 12 (7 - 21)
Most Current Plasma Concentration (mg/L)^5^
N | N/A | 4
Mean (SD) | N/A | 18 (4)
Median (Min, Max) | N/A | 20 (12 - 21)
31-50 | N/A | 0
<31 | N/A | 4

Note: If a lab event occurs multiple times at different severity levels while on caffeine, the first occurrence of the most severe event is used in the dose-response analyses.

Analyses include all caffeine doses received until the end of the event day.

1 Cumulative Dose-Participants With Event:cumulative caffeine dose from study start to the day of the event. Participants Without Event: the cumulative dose while on caffeine.

2 Maximum Dose-Participants With Event: maximum daily caffeine dose up to the day of the event. Participants Without Event: maximum daily dose while on caffeine.

3 Most Current Dose-Participants With Event: the daily caffeine dose on the day of the event.

4 Maximum Plasma Concentration-Participants With Event: maximum plasma concentration up to the day of the event. Participants Without Event: maximum plasma concentration while on study caffeine.

5 Most Current Plasma Concentration-Participants With Event: the most closed plasma concentration to the day of the event (within 7 days either before or after the event).

Table 14.3.1 Summary of Study Doses and Concentration by Site Safety Population

| Site | | | | Total; (N=410)
| ▬; (N=100) | ▬; (N=108) | ▬; (N=107) | ▬; (N=95) | Total; (N=410)
Mean Study Dose (mg/kg/day)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 9 (1) | 8 (3) | 6 (2) | 9 (3) | 8 (3)
Median (Min, Max) | 9 (7 - 12) | 7 (4 - 13) | 6 (4 - 22) | 9 (4 - 25) | 8 (4 - 25)
Max Study Dose (mg/kg/day)^1^
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 23 (4) | 19 (7) | 22 (3) | 22 (4) | 21 (5)
Median (Min, Max) | 22 (18 - 33) | 18 (12 - 46) | 21 (9 - 31) | 20 (5 - 31) | 20 (5 - 46)
Cumulative Study Dose (mg/kg)
N | 100 | 108 | 107 | 95 | 410
Mean (SD) | 700 (216) | 400 (171) | 269 (128) | 551 (242) | 474 (251)
Median (Min, Max) | 666 (107 - 1231) | 380 (40 - 800) | 263 (24 - 621) | 538 (20 - 1129) | 455 (20 - 1231)
Duration of Study Treatment (days)
N | 53 | 91 | 79 | 71 | 294
Mean (SD) | 72 (20) | 58 (13) | 58 (17) | 65 (18) | 62 (17)
Median (Min, Max) | 69 (33 - 133) | 57 (33 - 106) | 56 (10 - 94) | 63 (34 - 119) | 60 (10 - 133)
Duration ≥13 days | 53 (100.0%) | 91 (100.0%) | 78 (98.7%) | 71 (100.0%) | 293 (99.7%)
Duration<13 days | 0 | 0 | 1 (1.3%) | 0 | 1 (0.3%)
Number of Days Prior to Discharge that Caffeine was Discontinued^2^ (days)
N | 53 | 91 | 79 | 71 | 294
Mean (SD) | 24.2 (15.9) | 36.9 (21.9) | 30.4 (12.6) | 26.9 (22.0) | 30.4 (19.3)
Median (Min, Max) | 21.0 (7.0 - 93.0) | 35.0 (7.0 - 156.0) | 29.0 (7.0 - 61.0) | 18.0 (7.0 - 109.0) | 27.0 (7.0 - 156.0)
Mean Plasma Concentration (mg/L)
N | 24 | 3 | 101 | 46 | 174
Mean (SD) | 25 (7) | 24 (2) | 16 (3) | 24 (8) | 20 (7)
Median (Min, Max) | 26 (2 - 36) | 24 (22 - 26) | 16 (11 - 24) | 24 (7 - 41) | 18 (2 - 41)
Max Plasma Concentration (mg/L)
N | 24 | 3 | 101 | 46 | 174
Mean (SD) | 28 (8) | 24 (2) | 24 (5) | 27 (9) | 25 (7)
Median (Min, Max) | 29 (2 - 39) | 24 (22 - 26) | 24 (12 - 34) | 27 (7 - 44) | 25 (2 - 44)

Note: The summary is at participant level.

1 Max study dose is also considered as the maximum loading dose.

2 The summary excludes the infants dischaged due to death and discharged home <7 days last caffeine dose.

Table 14.3.2 Concomitant Medications by Drug Classification, Drug Name and Site Safety Population

Drug Classification; Medication Name | Site
Drug Classification; Medication Name | ▬; (N=100) | | ▬; (N=108) | | ▬; (N=107) | | ▬; (N=95) | | All Participants; (N=410)
Drug Classification; Medication Name | Participants With Medication; N (%) | Total Medications; N | Participants With Medication; N (%) | Total Medications; N | Participants With Medication; N (%) | Total Medications; N | Participants With Medication; N (%) | Total Medications; N | Participants With Medication; N (%) | Total Medications; N
ALIMENTARY TRACT AND METABOLISM | 1 (1%) | 1 | 4 (3.7%) | 4 | 7 (6.5%) | 7 | 18 (18.9%) | 18 | 30 (7.3%) | 30
OMEPRAZOLE | 0 | 0 | 0 | 0 | 2 (1.9%) | 2 | 0 | 0 | 2 (0.5%) | 2
RANITIDINE | 1 (1%) | 1 | 4 (3.7%) | 4 | 5 (4.7%) | 5 | 18 (18.9%) | 18 | 28 (6.8%) | 28
ANTIINFECTIVES FOR SYSTEMIC USE | 40 (40%) | 45 | 63 (58.3%) | 69 | 23 (21.5%) | 23 | 76 (80%) | 79 | 202 (49.3%) | 216
ERYTHROMYCIN | 0 | 0 | 56 (51.9%) | 56 | 1 (0.9%) | 1 | 73 (76.8%) | 73 | 130 (31.7%) | 130
FLUCONAZOLE | 39 (39%) | 39 | 12 (11.1%) | 12 | 22 (20.6%) | 22 | 4 (4.2%) | 4 | 77 (18.8%) | 77
MICONAZOLE | 4 (4%) | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 4 (1%) | 4
RIFAMPIN | 2 (2%) | 2 | 1 (0.9%) | 1 | 0 | 0 | 2 (2.1%) | 2 | 5 (1.2%) | 5
CARDIOVASCULAR SYSTEM | 91 (91%) | 182 | 100 (92.6%) | 294 | 63 (58.9%) | 124 | 90 (94.7%) | 245 | 344 (83.9%) | 845
AMLODIPINE | 7 (7%) | 7 | 0 | 0 | 0 | 0 | 0 | 0 | 7 (1.7%) | 7
BUMETANIDE | 1 (1%) | 1 | 8 (7.4%) | 8 | 0 | 0 | 0 | 0 | 9 (2.2%) | 9
CHLOROTHIAZIDE | 4 (4%) | 4 | 28 (25.9%) | 28 | 20 (18.7%) | 20 | 3 (3.2%) | 3 | 55 (13.4%) | 55
DOBUTAMINE | 10 (10%) | 10 | 14 (13%) | 14 | 2 (1.9%) | 2 | 0 | 0 | 26 (6.3%) | 26
DOPAMINE | 24 (24%) | 24 | 69 (63.9%) | 69 | 20 (18.7%) | 20 | 0 | 0 | 113 (27.6%) | 113
EPINEPHRINE | 8 (8%) | 8 | 10 (9.3%) | 10 | 2 (1.9%) | 2 | 10 (10.5%) | 10 | 30 (7.3%) | 30
FUROSEMIDE | 55 (55%) | 55 | 90 (83.3%) | 90 | 28 (26.2%) | 28 | 73 (76.8%) | 73 | 246 (60%) | 246
HYDROCHLOROTHIAZIDE | 0 | 0 | 0 | 0 | 0 | 0 | 2 (2.1%) | 2 | 2 (0.5%) | 2
IBUPROFEN | 15 (15%) | 15 | 15 (13.9%) | 15 | 9 (8.4%) | 9 | 1 (1.1%) | 1 | 40 (9.8%) | 40
INDOMETHACIN | 57 (57%) | 57 | 58 (53.7%) | 58 | 43 (40.2%) | 43 | 38 (40%) | 38 | 196 (47.8%) | 196
MILRINONE | 1 (1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (0.2%) | 1
PHENYLEPHRINE | 0 | 0 | 0 | 0 | 0 | 0 | 86 (90.5%) | 86 | 86 (21%) | 86
PROPRANOLOL | 0 | 0 | 2 (1.9%) | 2 | 0 | 0 | 0 | 0 | 2 (0.5%) | 2
SPIRONOLACTONE | 0 | 0 | 0 | 0 | 0 | 0 | 32 (33.7%) | 32 | 32 (7.8%) | 32
NERVOUS SYSTEM | 94 (94%) | 338 | 81 (75%) | 204 | 39 (36.4%) | 69 | 67 (70.5%) | 103 | 281 (68.5%) | 714
ACETAMINOPHEN | 81 (81%) | 81 | 21 (19.4%) | 21 | 1 (0.9%) | 1 | 47 (49.5%) | 47 | 150 (36.6%) | 150
FENTANYL | 60 (60%) | 60 | 67 (62%) | 67 | 31 (29%) | 31 | 31 (32.6%) | 31 | 189 (46.1%) | 189
LIDOCAINE | 31 (31%) | 31 | 14 (13%) | 14 | 0 | 0 | 4 (4.2%) | 4 | 49 (12%) | 49
LORAZEPAM | 42 (42%) | 42 | 38 (35.2%) | 38 | 1 (0.9%) | 1 | 0 | 0 | 81 (19.8%) | 81
MIDAZOLAM | 65 (65%) | 65 | 20 (18.5%) | 20 | 13 (12.1%) | 13 | 7 (7.4%) | 7 | 105 (25.6%) | 105
MORPHINE | 50 (50%) | 50 | 25 (23.1%) | 25 | 21 (19.6%) | 21 | 10 (10.5%) | 10 | 106 (25.9%) | 106
PHENOBARBITAL | 9 (9%) | 9 | 18 (16.7%) | 18 | 2 (1.9%) | 2 | 4 (4.2%) | 4 | 33 (8%) | 33
PHENYTOIN | 0 | 0 | 1 (0.9%) | 1 | 0 | 0 | 0 | 0 | 1 (0.2%) | 1
SYSTEMIC HORMONAL PREP., EXCL. SEX HORM. AND INSULIN | 30 (30%) | 30 | 37 (34.3%) | 37 | 10 (9.3%) | 10 | 10 (10.5%) | 10 | 87 (21.2%) | 87
HYDROCORTISONE | 30 (30%) | 30 | 37 (34.3%) | 37 | 10 (9.3%) | 10 | 10 (10.5%) | 10 | 87 (21.2%) | 87

Note: The percentages are the number of participants in the Safety Population in each site and overall.

Participants are counted once at each Drug classification and drug name.