# 5 Ethics

## 5.1 Institutional Review Board

The sponsor ensured that the protocol was reviewed and approved by the Duke University Institutional Review Board (IRB) prior to the start of any study activities. The IRB was appropriately constituted and performed its functions in accordance with United States (US) Food and Drug Administration (FDA) regulations, the International Council on Harmonisation’s guidelines for Good Clinical Practice (ICH GCP), and local requirements as applicable. Any amendments to the protocol received IRB approval prior to implementation of any changes made to the study design.

During the retrospective chart review process for data gathered from Electronic Health Records (EHR), each participating site was required to meet regulatory and institutional requirements for the protection of confidentiality of participant. Detailed IRB information for the sites which participated in the retrospective chart review process is provided in Appendix 16.1.3. Each site permitted authorized representatives of the sponsor, his designees, and appropriate regulatory agencies to examine (and, when required by applicable law, to copy) clinical records for the purposes of quality assurance reviews, audits, and evaluation of the study safety and progress. Representatives were permitted access to all source data, which included, but was not limited to, hospital records, clinical charts, laboratory notes, pharmacy dispensing records, recorded data from automated instruments, copies or transcriptions certified after verification as being accurate and complete, and participant files and records kept at the pharmacy and at the laboratories.

## 5.2 Ethical Conduct of the Study

This study was conducted in accordance with the ethical principles originating from the Declaration of Helsinki and current GCP, and in compliance with federal, state and local regulatory requirements including Code of Federal Regulations (CFR) Title 21 Parts 50, 56, and 312.

## 5.3 Participant Information, Consent, and Assent

For EHR data gathered from Pediatric Trials Network (PTN) sites, the reviewing IRBs at participating sites granted a waiver of informed consent since no new participants prospectively treated with caffeine citrate were enrolled in this study, and a retrospective safety evaluation could not be practically performed if informed consent was required.

Participant information collected in this study complied with the standards for protection of privacy of individually identifiable health information as promulgated by HIPAA and as mandated in Title 45 CFR Parts 160 and 164.

Data obtained from electronic health records (EHR) may have contained protected health information (PHI) and were therefore coded so that participants were identified by code numbers and not by name. Data extracted from EHR, including medical and pharmacy records, were permitted to be reviewed in order to meet federal or state regulations. Reviewers may have included the FDA, IRB(s), the sponsor and his representatives, and the National Institutes of Health (NIH).

Data obtained from the Pediatrix Medical Group database and the Prematurity and Respiratory Outcomes Program (PROP) study were de-identified in accordance with the Health Insurance Portability and Accountability Act (HIPAA) Privacy Rule (45 CFR 164.514 (a) and (b)) prior to transmission to investigators.

Appropriate and adequate provisions for ensuring participant privacy and data confidentiality were maintained by the participating investigators, their staff, the sponsor, and their agents. Data access was limited to study personnel, and the data were stored on servers which had limited physical access (e.g., locked rooms) and limited electronic access (e.g., password controlled access to data, computers and, if applicable, networks). The study protocol, documentation, data, and all other information generated by this study were maintained in a secure manner and were kept confidential as required by law. No information concerning the study or the data was released to any third party without prior written approval of the sponsor.