# 16 Appendices

16.1 Study Information
  16.1.1 Protocol
  16.1.2 Sample Case Report Forms
  16.1.3 Institutional Review Boards (IRBs) and Consent Information
  16.1.4 Description of Investigators
  16.1.5 CSR Signature Pages
  16.1.6 Listing of Study Drug Batch Numbers
  16.1.7 Randomization Scheme and Codes
  16.1.8 Audit Certificates
  16.1.9 Statistical Analysis Plans
  16.1.10 Laboratory Quality Assurance
  16.1.11 Publication Based on the Study
  16.1.12 Important Publications Referenced in the Report
16.2 Participant Data Listings (EHR data)
16.3 Case Report Forms for Participants with SAEs (EHR data)
16.4 Additional Data and Information
  16.4.1 Pediatrix Data
    16.4.1.1 Pediatrix Database Report
    16.4.1.2 Pediatrix Datasets (CAF01_Pediatrix.xpt) and Data Dictionary (Pediatrix-define.pdf)
  16.4.2 PROP Data
    16.4.2.1 PROP Report
    16.4.2.2 PROP Datasets and Data Dictionaries (PROP-define and PROP_2-define.pdf)
  16.4.3 Literature Review
16.5 EHR Data
  16.5.1 EHR Datasets and Data Dictionary (EHR-define.pdf)
  16.5.2 Dose-Exposure Simulations Datasets (cafsim.xpt), Data Dictionary (cafsim-define.pdf), Code, and Summary of Methodology

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/19261