# 4 GLOSSARY OF ABBREVIATIONS AND TERMS

Abbreviation: Definition
AE: Adverse Event
ALT: Alanine Transaminase
AST: Aspartate Transaminase
BMI: Body Mass Index
BPCA: Best Pharmaceuticals for Children Act
CFR: Code of Federal Regulations
CL: Clearance
CRA: Clinical Research Associate
eCRF: Electronic Case Report Form
DCC: Data Coordinating Center
DCRI: Duke Clinical Research Institute
DOL: Day of Life
ECMO: Extracorporeal Life Support
EDC: Electronic Data Capture
GA: Gestational Age
ICU: Intensive Care Unit
IV: Intravenous
Kg: Kilogram
mcg: Microgram
MIC: Minimum Inhibitory Concentration
ng: Nanogram
NICHD: Eunice Kennedy Shriver National Institute of Health and Human Development
NICU: Neonatal Intensive Care Unit
NIH: National Institutes of Health
PHI: Protected Health Information
PK: Pharmacokinetics
PD: Pharmacodynamics
PMA: Post menstrual age
PNA: Post natal age
PPRU: Pediatric Pharmacology Research Unit
PTN: Pediatric Trials Network
SAE: Serious Adverse Event
SvAE: Severe Adverse Event
SCR: Serum Creatinine
SOC: Standard of Care (per prescribing physician)
V: Volume of Distribution
VLBW: Very Low Birth Weight
WBC: White Blood Cell
WTKG: Weight in Kilograms