# 2 SYNOPSIS

NAME OF IND SPONSOR/COMPANY:

Daniel K Benjamin Jr., MD, PhD, MPH; Duke Clinical Research Institute

NAME OF FUNDING SPONSOR:Eunice Kennedy Shriver National Institute of Child Health and Human Development, National Institutes of Health (NICHD)

NAME OF FINISHED PRODUCT: | NAME OF ACTIVE INGREDIENT:
Ampicillin | Ampicillin

TITLE OF STUDY: Ampicillin Pharmacokinetics and Safety in Infants

PRINCIPAL | Daniel K Benjamin Jr., MD, PhD, MPH
INVESTIGATORS: | Duke Clinical Research Institute (DCRI)

PUBLICATION (REF): Tremoulet A, Le J, Poindexter B, Sullivan JE, Laughon M, Delmore P, Salgado A, Chong SI, Melloni C, Gao J, Benjamin DK, Capparelli EV, Cohen-Wolkowiez M. Characterization of the Population Pharmacokinetics of Ampicillin in Neonates Using an Opportunistic Study Design. Antimicrob. Agents Chemother. 2014;58(6):3013-3020.

STUDY PERIOD FOR PK STUDY: | PHASE OF DEVELOPMENT:
February 16, 2012 – August 1, 2012 | PK Analysis – Phase 1; Retrospective Safety Analyses – Phase 4

PRIMARY OBJECTIVES:

1. Characterize the PK of ampicillin from samples obtained in a PK study of ampicillin
2. Characterize safety of ampicillin prescribed to infants per standard of care (SOC) by their treating caregiver

METHODOLOGY FOR PK STUDY:

Sparse sampling, PK/PD modeling

NUMBER OF PARTICIPANTS (ANALYZED):

- PK Analysis:
  - 75 participants (infants) enrolled under the NICHD-2011-POP01 study.
- Safety Analysis:
  - 75 participants (infants) enrolled under the NICHD-2011-POP01 study.
  - 199,785 infants who received ampicillin in the Pediatrix Medical Group Database (NICHD-2012-AMP01).
  - 68 participants (infants) who received ampicillin while enrolled in the Pediatric Pharmacology Research Unit (PPRU) study at ▬ (NICHD-2012-AMP01).

DIAGNOSIS AND MAIN CRITERIA FOR INCLUSION:

PK and Safety (NICHD-2011-POP01)

- Inclusion Criteria
  Infants with a postnatal age < 30 days who were receiving ampicillin per standard of care
- Exclusion Criteria
  Failure to obtain consent/assent (as indicated)

Safety (NICHD-2012-AMP01)

- Inclusion Criteria
  Infants enrolled in the PPRU Antimicrobial PK in High Risk Infants study at ▬▬▬▬▬ and infants exposed to ampicillin discharged from a NICU managed by the Pediatrix Medical Group between 1997 and 2010.
- Exclusion Criteria
  None

TEST PRODUCT, DOSE AND MODE OF ADMINISTRATION, BATCH NUMBER:

Objective 1 - PK Analysis – Ampicillin is a generic therapeutic and was supplied by the site clinical pharmacy.

Objective 2 - Safety Analysis - This was a secondary data analysis study. The administration of ampicillin study drug was not a part of this protocol.

CRITERIA FOR EVALUATION:

Efficacy: Efficacy evaluation of the drugs under study was beyond the scope of this investigation.

PK: The PK analysis assessed clearance (CL) and volume (V) through compartmental population modeling (nonlinear mixed effects modeling in NONMEM). In addition, the proportion of simulated participants infants with a trough concentration above the minimum inhibitory concentration (MIC) of ≥8 mcg/mL (the MIC_90 per CLSI breakpoints) was evaluated as the surrogate PD endpoint in simulations.

Safety:

- NICHD-2011-POP01 study: Adverse Events (AEs) and Serious Adverse Events (SAEs) caused by study specimen collections were reported at each time point when the study specified biological sample collection occurred up until 1 hour after collection. Serious, unexpected, suspected adverse reactions of the understudied drug of interest were reported from the time of first biological sample collection until 3 days after the last biological sample was collected if participant was available. AE information was gained from direct monitoring of the study subject as well as from clinician observation, and self-reporting by the study subject or his/her guardian(s).
- Pediatrix Database: AE and severe AE (SvAE) were defined by pre-specified diagnosis and laboratory cut-offs.
- Retrospective chart review (PPRU at ▬): AE and SvAE were collected through retrospective chart review. Frequency of AE and SvAE, microbiological data, physical examination findings and growth parameters (weight, height and head circumference) collected at the beginning and at the end of the study were reported.

STATISTICAL METHODS:

Descriptive statistics such as number of observations, mean, median, standard deviation, standard error, minimum, and maximum are presented for continuous variables. Other descriptive statistics such as counts, proportions, and/or percentages are presented to summarize discrete variables (such as race, sex, etc.). Demographic and safety characteristics are summarized by gestational and postnatal age group. The percentage of days with each AE was determined for each dose and dosing interval. The median ampicillin exposure on days with and without each AE and SvAE was determined. The percentage of infant days with each AE and SvAE were determined for each decile of ampicillin exposure. These analyses were performed for all infants and by gestational and postnatal age group. These parameters were also determined with the analysis limited to infants with documented infection.

RESULTS:

PK/PD: A population PK analysis was performed on the plasma pharmacokinetic samples obtained in the NICHD-2011-POP01study. As this was an opportunistic PK study, the dosing of ampicillin was based on that chosen by the primary treating physician. The average total daily dosing of ampicillin prescribed for the participants in the study exceeded the most common dosing references (Neofax, Harriet Lane and Pediatric Drug Dosing). Neonates were stratified into 4 groups by gestational age (GA, ≤ 34 weeks or > 34 weeks) and postnatal age (PNA, ≤ 7 days or > 7 days).

Overall, a total of 160 ampicillin plasma concentrations in 75 participants were collected. Of these, a total of 142 ampicillin plasma concentrations in 73 participants were used to construct the population PK model. Data were fit to a 1-compartment model (ADVAN1 TRANS2) using NONMEM version 7.2 and the First Order Conditional Estimation method with ETA-EPS interaction (FOCE-I). Weight (WTKG) was assumed to be a significant covariate for CL (L/h) and V (L) and was included in the base model prior to assessment of other potential covariates. A univariable covariate screen was performed for potential associations with PK parameters. Both PMA- and GA/PNA-based models were constructed. Mechanistically, the final PMA-based model was better than GA/PNA-based model. The final population model is: V = θ_(1)_ * WTKG and CL = θ_(2)_ * WTKG * (0.6/SCR)^θ (3)^ (PMA/37)^θ (4)^; where θ_(1)_ =0. 399, θ_(2)_= 0.078, θ_(3)_ =0.428, and θ_(4)_ =1.34. The between-subject variability for CL was 23%, and the residual variability was 34%. Monte Carlo simulations (N=1920) were performed using the final model to determine the most clinically applicable optimal dosing regimen for achieving a trough concentration above the MIC of ≥8 mcg/mL in at least 90% of simulated participants. Dosing by GA/PNA and PMA (the latter using empirically-derived thresholds for PMA and PNA) achieved similar PD target attainment. The dosing regimen by GA/PNA was selected to offer the specificity needed to account for prematurity and developmental changes that occur with age, especially during the first 1 to 2 weeks of life, the dosing regimen was simplified to: 50 mg/kg every 12 hours for Group 1 (GA≤ 34 weeks and PNA≤ 7 days), 75 mg/kg every 12 hours for Group 2 (GA≤ 34 weeks and PNA 8-28 days) and 50 mg/kg every 8 hours for Groups 3 (GA> 34 weeks and PNA≤ 7 days) and 4 (GA>34 weeks and PNA 8-28 days).

Efficacy: No efficacy analyses were conducted as part of this study.

SAFETY:

No adverse events or reactions were reported from the NICHD-2011-POP01 study.

From the Pediatrix Database: Adverse events during ampicillin exposure were uncommon. Shorter dosing intervals were associated with more frequent hematologic AEs for infants of all age groups. Thrombocytopenia was the most common laboratory AE occurring on 3.4% of infant-days. Thrombocytopenia occurred more frequently at shorter dosing intervals. There was no obvious relationship between ampicillin dose or exposure and thrombocytopenia. Leukopenia AE and SvAE occurred at higher ampicillin exposures for the youngest infants (Group 1). There was no clear relationship between ampicillin exposure and leukopenia for older infants (Groups 2 & 3). Ampicillin exposure was not clearly related to neutropenia AE and SvAE.

AST elevation was very uncommon occurring on approximately 0.1% of infant-days. AST AE and SvAE appeared to occur sporadically with no obvious relationship to ampicillin dose or dosing interval. No infants with documented infection had an AST AE or SvAE during ampicillin exposure. Most AST AEs and SvAEs occurred in the youngest infants (Group 1).

Seizures occurred more frequently with higher doses of ampicillin and shorter dosing intervals and occurred on 0.3% of infant-days. The association of ampicillin exposure with seizure was unclear: infant-days on which a seizure occurred tended to have higher ampicillin exposures but infant-days with the highest exposures often did not have a seizure occur.

CONCLUSIONS:

PK: The final population model is:

V (L) = θ_(1)_ * WTKG

CL (L/h) = θ_(2)_ * WTKG * (0.6/SCR)θ_(3)_ (PMA/37)θ_(4)_

Here, θ_(1)_ =0. 399, θ_(2)_= 0.078, θ_(3)_ =0.428, and θ_(4)_ =1.34. This population pharmacokinetics study of ampicillin in participants demonstrated the importance of PMA, composed of PNA and GA, in drug CL.

The Monte Carlo simulation for the surrogate PD endpoint demonstrated that the higher dose of ampicillin currently being prescribed by most physicians, and demonstrated by the average daily dose of ampicillin ordered by the primary caregiver for the participants in NICHD-2011-POP01, achieved the surrogate PD endpoint of trough concentrations at steady state ≥8 mcg/mL in >97% of virtual subjects as compared to 90% of virtual subjects with the current dosing references. As the goal was to achieve a trough concentration above the MIC of ≥8 mcg/ml in at least 90% of the infants, we devised the following dosing regimen that simplifies the current dosing references:

Gestational age (weeks) | Postnatal age (days) | Maintenance dose (mg/kg) | Dosing interval (hours)
≤ 34 | ≤ 7 | 50 | 12
≤ 34 | ≥ 8 & ≤ 28 | 75 | 12
> 34 | ≤ 28 | 50 | 8

Safety: In the Pediatrix database, adverse events of special interest during exposure to ampicillin were uncommon. Seizure occurred more frequently at higher doses. Seizure, neutropenia, leukopenia and thrombocytopenia occurred more frequently at shorter dosing intervals. Shorter dosing interval had the greatest influence on the incidence of AEs. Safety events at the dosing regimen suggested above resulted in AEs and SvAEs occurring at rates equal to or less than other dosing regimens.

DATE OF THE REPORT: November 24, 2014