# 13 DISCUSSION AND OVERALL CONCLUSIONS

## 13.1 Discussion

Ampicillin is a commonly used drug in infants. However, the lack of pharmacokinetic studies in premature infants and lack of uniformity of dosing has led to a variety of doses being used based on factors including GA, PNA, weight and PMA. As the PK study was an opportunistic study, the study did not control for dosing. Dosing ranged from 100-350 mg/kg/day and generally exceeded the recommended dosing in the most commonly pediatric dosing handbooks (Neofax, Harriet Lane and Pediatric Dosage Handbook). The high dose of prescribed ampicillin appears to stem from concerns for meningitis in the infants being treated.

The present PK study evaluated the population PK of ampicillin in 73 infants as young as 24 weeks gestation and up to 28 days postnatal age. This population PK model allowed us to characterize the CL and V of ampicillin in these infants but we were limited in looking at intra-variability because we had an average of only two samples per subject. A 1-compartment model appropriately described the data and was precise as evidenced by population CL and V point estimates nearly identical to the median bootstrap values and narrow 95% confidence intervals. A maturational change in ampicillin clearance was included in the final model through the PMA and SCR covariates. Given the low exponent value of 0.42 for SCR, it was not as important as the PMA (which is composed of PNA and GA) with an exponent value of 1.3.

The Monte Carlo simulation demonstrated that the higher dose of ampicillin currently being prescribed by most physicians, demonstrated by the average daily dose of ampicillin ordered by the primary caregiver for the infants in POPS, achieved the surrogate PD endpoint of trough concentrations at steady state >8 mcg/ml in >97% of virtual subjects as compared to 90% of virtual subjects with the current dosing references. As the goal was to achieve a trough concentration above the MIC of ≥8 mcg/ml in at least 90% of the infants, we devised a dosing regimen that simplifies the current dosing references.

## 13.2 Overall Conclusions

The population pharmacokinetics study of ampicillin in infants demonstrated the importance of PMA, composed of PNA and GA, in drug CL. The current dose used by most practitioners in infants appears to provide a higher dose than pharmacologically necessary. We were able to simplify the dosing regimens from several references and devise a simplified dosing regimen for ampicillin based on the 4 groups used in this study: 50 mg/kg every 12 hours for Group 1, 75 mg/kg every 12 hours for Group 2 and 50 mg/kg every 8 hours for Groups 3 and 4 (Table 11-5). This achieved a trough concentration above the MIC of ≥8 mcg/ml in at least 90% of the infants. Furthermore, although some references suggest every 6 hour dosing for some PNA and GA groups, adjusting the total dose would allow for every 8 hour dosing, simplifying the frequency of ampicillin administration.

The safety analysis shows that ampicillin is generally safe. Leukopenia, neutropenia and thrombocytopenia increased in incidence with shorter dosing intervals. Seizures were more common with higher doses and shorter dosing intervals.