# 12 SAFETY EVALUATION

Safety was primarily assessed using data from retrospective chart review of participants enrolled in a prior PPRU study and using a large epidemiological database from the Pediatrix Medical Group. Safety data collected from the NICHD-2011-POP01 study were analyzed as well.

## 12.1 NICHD-2011-POP01

No adverse events or reactions were reported in this study.

## 12.2 PPRU Safety Analysis

In this study of 68 infants exposed to ampicillin, 46 (68%) experience one of the pre-specified diagnoses. Laboratory abnormalities were less common, with 19 infants (28%) having leukocytosis, the most common laboratory abnormality.

## 12.3 Pediatrix Safety Analysis

Seizures occurred more often at doses ≥250 mg/kg/dose and at dosing intervals ≤6 hours. AST elevation occurred more often at higher ampicillin exposures. Leukopenia, neutropenia and thrombocytopenia occurred more often at shorter dosing intervals ≤6 hours and thrombocytopenia occurred more often at higher ampicillin exposures.

## 12.4 Safety Conclusions

Based on this safety analysis from three separate data sources, ampicillin was associated with few AEs. AEs were uncommon in the Pediatrix database. Some, but not all, AEs were related to higher doses, shorter dosing intervals and higher ampicillin exposures.