# 10 STUDY PATIENTS – NICHD-2011-POP01 STUDY

## 10.1 Disposition of Participants

Participant accounting is summarized in Table 10-1 and in Section 14, Table 14.1.1.1. A total of 75 participants were consented for the study and had available PK samples. Participants were enrolled based on PNA and GA. One participant with a PNA of 30 days was enrolled into the study and is included in the 8-28 day group. As discussed in Section 11.4.1, this participant is not included in the PK analysis. The largest group, participants with a PNA ≤ 7 days and GA > 34 weeks, enrolled 27 participants. The smallest group, participants with a PNA of 8-28 days and GA ≤ 34 weeks, enrolled 8 participants.

Table 10-1 Participant disposition by PNA and GA group

| [underlined: PNA ≤ 7 Days] | | [underlined: PNA = 8-28 Days]
| GA ≤ 34 weeks | GA > 34 weeks | GA ≤ 34 weeks | GA >34 weeks | Total
Number of Enrolled Participants | 21 | 27 | 8 | 19 | 75
Number of Participants with At Least 1 Available Plasma Sample | 21 | 27 | 8 | 19 | 75
Number of Participants with Research-Only Samples | 6 | 14 | 3 | 5 | 28

All 75 enrolled participants were eligible for the safety analysis. Twenty-eight (37%) of the 75 participants had research-only samples collected and were eligible for the AE safety analysis associated with the collection of research-only samples.

As shown in Table 14.1.1.2, 42 (56%) of the 75 participants were enrolled at one site, ▬▬▬▬▬. Four of the 9 sites enrolled 2 or fewer participants.

## 10.2 Protocol Deviations and Waivers

Tables 14.1.3.1-3 summarize participant specific protocol deviations. All participant specific deviations are presented in Listing 16.2.5. As seen in Table 14.1.3.1-2, 12 deviations were reported in 9 (12%) enrolled participants. Eight (67%) of the 12 deviations were related to informed consent and 1 (8%) was related to protocol procedure or assessment. Listing 16.2.5 shows that the deviation related to protocol procedure was due to a sample that was not spun in a refrigerated centrifuge. Deviations related to informed consent were due to one of the following reasons – signature by the wrong site personnel, delayed signature on the HIPAA consent form with respect to the ICF, and exclusion of HIPAA authorization forms for the substudy from the initial informed consent packet. No site specific deviations (such as sample shipping deviations) were reported for sites while enrolling ampicillin participants.