# 9 INVESTIGATIONAL PLAN: NICHD-2011-POP01

## 9.1 Overall Study Design and Plan Description

As discussed in Section 7.7, Sections 9-11 of this CSR discuss study design and analyses associated with PK data collected as part of the NICHD-2011-POP01 protocol (Appendix 16.4.1) in infants administered ampicillin per standard of care. This was an open label, multi-center, opportunistic PK study of drugs administered per routine medical care. Participants were not prescribed ampicillin as a part of this protocol. A legal guardian of the participant meeting inclusion criteria in the inpatient hospital setting was approached for consent for this study.

## 9.2 Discussion of Study Design

The NICHD-2011-POP01 ampicillin PK data was collected through an open label, opportunistic study design. No control groups were included in this study. The dosing, sampling, and demographic information recorded on the electronic Case Report Form (eCRF) was merged with the bioanalytical information to create a PK dataset for ampicillin. Because a sparse sampling scheme was employed in this study, population PK methodologies were used to analyze the PK data.

## 9.3 Study Population

A total of 64 participants were planned for enrollment in this study. As shown in Table 9-1, 16 participants were scheduled to be enrolled in each strata separated by post-natal age (PNA) and gestation age (GA).

Table 9-1 Planned sample size in each PNA and GA cohort

PNA (Days) | ≤ 7 | | 8-28
GA Groups (Weeks) | ≤ 34 | > 34 | ≤ 34 | > 34
Group Number | 1 | 3 | 2 | 4
Planned Sample Size | 16 | 16 | 16 | 16

### 9.3.1 Inclusion Criteria

Children (< 21 years of age) who were receiving understudied drugs of interest per standard of care as prescribed by their treating caregiver were eligible for the NICHD-2011-POP01 protocol. Infants who were receiving ampicillin per standard of care and belonged to one of the enrollment groups in Table 9-1 were targeted for inclusion in the ampicillin analysis.

### 9.3.2 Exclusion Criteria

1. Failure to obtain consent/assent (as indicated).

### 9.3.3 Removal of Subjects from Assessment

1. Parents or legal guardians of participants who withdrew consent to participate in the study and requested no further follow-up were terminated from the study.
2. In cases of early / premature termination (defined as a participant with no samples obtained / drawn for the study and / or participant withdrawn from the study), a replacement participant could be enrolled.

Participants could be enrolled in the NICHD-2011-POP01 protocol under multiple drugs of interest, but they could not be enrolled multiple times for the same drug.

## 9.4 Treatments

Ampicillin was administered in accordance with local standard of care as prescribed by the treating caregiver. Participants continued standard therapy for existing acute or chronic medical conditions.

### 9.4.1 Identity of Investigational Products

Ampicillin is a generic therapeutic and was supplied by the site clinical pharmacy.

### 9.4.2 Blinding

This was an open-label study and no study treatments were blinded or masked.

### 9.4.3 Prior and Concomitant Therapy

Presence of the concomitant medication of interest – probenecid – within 24 hours before and/or after any dose of ampicillin closest to the time of biological sample collection was recorded.

### 9.4.4 Treatment Compliance

All participants were under the care of a primary physician. Therefore each dose of drug administration was given and monitored by clinical staff, then reviewed by study personnel. The prescription of drugs to participants was not part of this protocol.

## 9.5 Pharmacokinetic and Safety Variables

### 9.5.1 Pharmacokinetic Variables

The PK analysis assessed clearance (CL) and volume (V) through compartmental population modeling. As part of a secondary analysis, the proportion of simulated infants with a trough concentration above the minimum inhibitory concentration (MIC) of ≥8 mcg/mL in at least 90% of simulated participants was used for a surrogate PD endpoint in simulations. This breakpoint was used as it is the MIC per the Clinical and Laboratory Standards Institute (CLSI) needed to inhibit growth of 90% of Escherichia coli organisms, a common pathogenic infection in infants [22].

### 9.5.2 Safety Variables

AEs or serious adverse events (SAE) related to study procedures (collection of biological samples for research purposes) and serious, unexpected, suspected adverse reactions of ampicillin were the only safety variables in the NICHD-2011-POP01study.

AEs and SAEs caused by the study specimen collections were reported at each time point when the study specified biological sample collection occurred up until 1 hour after collection. AE information was gained from direct monitoring of the study subject as well as from clinician observation, and selfreporting by the study subject or his/her guardian(s).

Serious, unexpected, suspected adverse reactions of the understudied drug of interest were reported from the time of first biological sample collection until 3 days after the last biological sample was collected if infant was available.

### 9.5.3 Schedule of Assessments

After a participant was enrolled in the study the following information was recorded/collected on Day 1 through Day 90 or until a Termination Visit, whichever occurred first:

Sampling Information:

1. Exact date and time the sample was drawn
2. Exact date and time the sample was frozen/stored
3. Sample volume (estimated)
4. Sample type (i.e. plasma)
5. Sample acquisition site
6. Correlation to flush

Ampicillin Information:

1. Exact infusion start and end date and time of previous dose of drug of interest
2. Dose amount
3. Dose number
4. Dose frequency
5. Indication
6. Dosing weight
7. Actual weight
8. Route of administration
9. Indication

Ampicillin information for up to 8 doses prior to the sampling dose (last dose prior to first biological sample collection) was recorded.

Concomitant Medication Information (Probenecid):

1. Presence of the only concomitant medication of interest, probenecid, within 24 hours before and after the dose of drug of interest closest to the time of biological sample collection
2. Date and time probenecid administered
3. Total daily dose (per day)
4. Route of administration

Demographic Information:

1. Age
2. Gender
3. Race
4. Ethnicity
5. Current weight
6. Current height/length
7. Gestational age at birth
8. Birth weight

Clinical Information (if available):

1. Serum creatinine
2. Plasma albumin
3. Aspartate aminotransferase (AST)
4. Alanine aminotransferase (ALT)
5. Bilirubin (total and direct)

For serum creatinine, plasma albumin, AST, ALT, and bilirubin, the concentration value as well as the date of collection was obtained. The laboratory data defined above was collected only if drawn within 24 hours before or after the dose of ampicillin closest to the time of biological sample collection. If more than 1 result was available within the 24 hour time frame, the result closest to the time of the dose of ampicillin was recorded. If more than 1 biological sample was collected within a 24 hour period, one serum creatinine, plasma albumin, AST, ALT, and/or bilirubin value (closest to the time of the dose of ampicillin) was obtained. If biological samples were collected in a span of more than 1 day, above laboratory data was collected each day of biological sample collection and closest to the time of the ampicillin dose closest to the time of biological sample collection.

## 9.6 Biological Sample Analysis

Each participant could have had no more than 10 research-only blood samples associated with ampicillin.

A PK sampling scheme was employed such that no more than a pre-determined weight-based maximum volume of blood for samples drawn for research purposes was obtained from each subject within a 30 day period as follows: ≤1 kg, 5 mL; 2kg, 10 mL; 3 kg, 12 mL; 4 kg, 16 mL; 5 kg, 20 mL; 6 kg, 24 mL.

After enrollment, biological samples were collected using recommended sampling windows (Figure 9-1) according to the below dosing interval (see Table 9-2). Participating sites were encouraged to collect biological samples when clinical specimens were being obtained per standard of care. However, the option to consent for sample collection for research purposes was given to the parent/guardian of the participating infant.

Fresh plasma samples collected as part of this study were sent to the a central laboratory for drug concentration measurements (PK samples). Samples were labeled only with a unique accession number without protected health information (PHI) that could identify the study subject. Once samples were analyzed, data were sent to the BPCA DCC and entered into the study records.

Table 9-2 Recommended sampling windows and dosing intervals for intravenous drug administration

| Dosing Interval (Hours)
Sample Name | 2 | 4 | 6 | 8 | 12 | 24 | 48 | 72
Sample #1 | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^
Sample #2 | 0.15-0.5 | 0.52 | 1-4 | 2-5 | 2-8 | 3-12 | 3-24 | 3-48
Sample #3 | Pre | Pre | Pre | Pre | Pre | Pre | Pre | Pre
Sample #4 (elimination) | 4-8 | 8-12 | 12-18 | 16-24 | 24-36 | 48-72 | 96-144 | 144-216

a Time 0 = end of infusion; collect sample after flush* ends

Pre = within 1 hour prior to next administration of study drug; d = days

Figure 9-1 Sample collection associated with Table 9-2

A flow chart of study procedures is presented in Table 9-3

Table 9-3 Flow chart of study procedures

Procedure | Day 0 Pre-Sample Collection | Day 1 Day of first sample collection | Day 1- up to Day 90/Termination Visit Day of any subsequent sample collection
Informed Consent/Permission/Assent | X
Infant Demographics | | X
Clinical Data^d^ | | X | X
Drug(s) of Interest Data | X^b^ | X^a^ | X^a^
Biological Sample Collection | | X^a^ | X^a,e^
Safety | | X | X^c^

a Procedure may be collected once on Day 1 and / or continued for up to 90 days for ampicillin according to drug frequency of administration and number of biological samples collected as per prescribing physician’s standard of care treatment. Site will store biological samples until batch shipped to testing lab or storage lab.

b Collect ampicillin information for up to 8 doses prior to the sampling dose (last dose prior to first biological sample collection).

c Serious, unexpected, suspected adverse reactions related to ampicillin will be reported from the time of first biological sample collection until 3 days after the last biological sample is collected if infant is available.

d May include lab collection (which could also be pre-sample collection)

e If infant is accessible, collect 1 PK plasma sample at time of identification of serious, unexpected, suspected adverse reactions of the understudied drug of interest.

### 9.6.1 Drug Concentration Measurements

An assay to measure ampicillin concentrations in collected specimens was performed at a central lab, OpAns Laboratory, using a validated bio-analytical assay (See Appendix 16.4.4 for validation report).

## 9.7 Data Quality Assurance

An electronic case report form (eCRF) was used to record infant data in the Advantage EDC^SM^ system. GlobalTrace^SM^ was used as an electronic specimen inventory. The eCRF was used for the recording of all historical infant information and study data as specified by this protocol. The eCRF was completed by designated and trained study personnel. Certain data elements were collected on provided source documents, but were not entered into the Advantage EDC system.

Prior to the initiation of the study, the Pediatrics Trial Network selected sites that were fully capable of carrying out the study. The BPCA DCC trained the investigators, sub-investigators and their study coordinators in eCRF completion, study management tools, and regulatory compliance. The Duke Clinical Research Institute (DCRI) PI trained site staff on the protocol, performance of study procedures, and specimen collection methods. In addition to the investigators’ meeting, the study personnel at each site were trained on the study procedures by a DCRI Clinical Research Association (CRA) as necessary.

EMMES monitored each site throughout the study. At each visit, data recorded in the EDC system were compared to source documentation to ensure accuracy. Quality assurance checks were performed to ensure that the investigators were complying with the protocol and all applicable regulations. The data for primary outcomes were monitored.

In addition to the quality assurance checks incorporated into the EDC system, additional logic checks were run to check for such items such as inconsistent study dates and outlying laboratory values. Any necessary corrections were made by site staff in the eCRF and documented via audit trail, prior to study data lock.

## 9.8 Statistical Methods and Determination of Sample Size

Only participants enrolled for ampicillin as part of the NICHD-2011-POP01 protocol are included in the analysis described in Sections 10, 11, and 12. Participants were enrolled in the GA and PNA stratums specified in Section 9.3.1. All participants with at least one available plasma sample drawn for ampicillin were eligible for the PK analysis. All enrolled participants with at least one sample drawn were eligible for the safety analysis.

### 9.8.1 Statistical and Analytical Plans

Table summaries are stratified by the GA and PNA groups used to stratify enrollment. For continuous variables, descriptive statistics include number of observations, mean, standard deviation, median, minimum and maximum value. Discrete variable summaries include counts and proportions. Except for PK analyses, analyses and data summaries for the NICHD-2011-POP01 protocol were produced using SAS® Software version 9.2 or later. A generic Statistical Analysis Plan (SAP) was prepared for CSRs submitted for drugs of interest analyzed as part of the NICHD-2011-POP01 protocol and can be found in Appendix 16.1.9.

#### 9.8.1.1 Study Patient, Demographics, and Baseline Characteristics

##### 9.8.1.1.1 Disposition of Participants and Withdrawals

All participants with at least 1 sample drawn for ampicillin were accounted for in this analysis. A summary of participant accounting and final study disposition is provided.

##### 9.8.1.1.2 Inclusion and Exclusion criteria

Inclusion and exclusion criteria for each infant are summarized in Listing 16.2.2.

##### 9.8.1.1.3 Protocol Violations and Deviations

Protocol deviations were reported by site and category of deviation. A detailed listing of protocol deviations by participant is included. Deviations related to samples other than fresh plasma samples are not included in these summaries. Deviations were collected from enrollment of the first infant at the site to completion of the last infant at the site and are included in the site specific protocol deviation summary.

##### 9.8.1.1.4 Demographic and Baseline Characteristics and Data of Special Interest

Demographic and baseline variables include gender, ethnicity, race, gestational age, post natal age, height/length, and birth weight, Body Mass Index (BMI). Medical history such as diagnosis of cystic fibrosis, congenital heart disease and extracorporeal life support (ECMO) are also summarized.

#### 9.8.1.2 Safety Analyses

An adverse event is any untoward medical occurrence in humans, whether or not considered drug related which occurs during the conduct of a clinical trial.

Suspected adverse reaction is any adverse event for which there is a reasonable possibility that the drug caused the adverse event. A reasonable possibility implies that there is evidence that the drug caused the event.

Adverse reaction is any adverse event caused by the drug.

A serious adverse event or serious suspected adverse reaction or serious adverse reaction as determined by the Investigator or the sponsor is any event that results in any of the following outcomes:

1. Death
2. Life-threatening AE (Life-threatening means that the study participant was, in the opinion of the investigator or sponsor, at immediate risk of death from the reaction as it occurred.)
3. Inpatient hospitalization or prolongation of existing hospitalization
4. Persistent or significant incapacity or substantial disruption of the ability to conduct normal life functions
5. Congenital abnormality or birth defect
6. Important medical event that may not result in one of the above outcomes, but may jeopardize the health of the study participant or require medical or surgical intervention to prevent one of the outcomes listed in the above definition of serious event.

An unexpected adverse event is any adverse event, the specificity or severity of which is not consistent with the package insert or investigational plan or informed consent.

As all participants in this study had pre-existing medical conditions and were hospitalized, those pre-existing conditions were not considered as adverse events. AEs or serious adverse events (SAE) related to study procedures (collection of biological samples for research purposes) and serious, unexpected, suspected adverse reactions of understudied drug of interest were reportable in the data system.

##### 9.8.1.2.1 Planned Guidelines for Assessing Intensity of an Adverse Event

AEs related to study procedures (collection of biological samples) were planned to be graded as follows:

- Mild: Participant is aware of symptoms or has minor findings, but tolerates them well and no or minimal intervention required
- Moderate: Participant experiences enough symptoms or findings to require intervention
- Severe: Participant experiences symptoms or findings that require significant intervention

##### 9.8.1.2.2 Planned Guidelines for Determining Causality of an Adverse Event

The Investigator was to use the following question when assessing causality of an adverse event to study drug: Is there a reasonable possibility that the drug caused the event?

An affirmative answer would have designated the event as a suspected adverse reaction.

##### 9.8.1.2.3 Adverse Event Collection Period

AEs and SAEs caused by the study specimen collections were to be reported at each time point when the study specified biological sample collection occurs up until 1 hour after collection. AE information was to be gained from direct monitoring of the study subject as well as from clinician observation, and self-reporting by the study subject or his/her guardian(s).

AEs related to study procedures was to be followed until resolution even if this extended beyond the study-reporting period. Resolution of an AE is defined as the return to pretreatment status or stabilization of the condition with the expectation that it will remain chronic.

Serious, unexpected, suspected adverse reactions of the understudied drug of interest were to be reported from the time of first biological sample collection until 3 days after the last biological sample is collected if subject was available.

#### 9.8.1.3 Dosing, PK Sampling, and Laboratory values

Analysis of dosing includes summaries of dose route and strength for sampling doses associated with available PK plasma doses.

Analysis of sample collection includes the number of samples collected, number of samples in each sampling window, number collected after flush (when applicable), and a summary of time until freezing. Concentrations are summarized in tables by sampling window.

Clinical laboratory measurements are summarized. Only the closest lab measurement collected within 24 hours to the start of the sampling dose are included in the table summary. Baseline measurements were not available. All recorded values are included in listings.

#### 9.8.1.4 Pharmacokinetic Analysis

PK models for ampicillin concentration data were explored by non-linear mixed effects modeling using NONMEM. Appropriate compartmental models were examined, and between-subject variability on model parameters was explored. Data were fit to a 1-compartment model (ADVAN1 TRANS2) with proportionate residual error using NONMEM version 7.2 and the First Order Conditional Estimation method with ETA-EPS interaction (FOCE-I). Proportional and additive residual error models were explored. Diagnostic plots were used to assess the appropriateness of this structure for the base model.

Missing weight (WTKG) and serum creatinine (SCR) values were imputed with the last recorded value carried forward. If an infant did not have serum creatinine (SCR) measured during the study period, SCR values were imputed based on NICHD-2011-POP01 population median value. Covariate analysis examined the correlation between model parameters with demographic factors. Weight (WTKG) was assumed to be a significant covariate for CL and V and was included in the base model prior to assessment of other potential covariates.

The investigation of the relationship between potential covariates and PK parameters proceeded by estimating the basic population PK model with the generation of the Bayesian individual PK parameters (e.g., CL and V). With these individual parameter estimates, their deviation from the typical population parameter values were also generated; individual subject ETAs (η). Next, graphical assessment of the relationships between PK parameters and potential covariates was performed by plotting ETAs versus potential clinically relevant covariates. Clinical variables were evaluated as potential covariates for PK parameters using a univariate screen in NONMEM followed by a multivariate assessment of the final population PK model. The following potential covariates were included in the univariable analysis: SCR, days of life (DOL, which is PNA plus 1), GA, post menstrual age (PMA), and sex. The construction of a final population PK model was done with all variables as indicated from the multivariable exploration if applicable, NONMEM univariate screen, and graphical exploration.

During the model building process, potential covariates that reduced the objective function by more than 3.84 (p<~0.05) were planned for inclusion in the subsequent multivariate analysis. A forward inclusion approach with backwards elimination was planned for the multivariate step, and a reduction of 7.88 (p<~0.005) was required for retention of a covariate in the final model.

Standard model diagnostic plots and procedures were used to evaluate model appropriateness. Empirical Bayesian estimates of individual subject PK parameters were generated from the final model. Model evaluation was performed by visual predictive check, standard visual predictive check, and bootstrapping procedures as needed. Monte Carlo simulations were performed using the final model to determine the most clinically applicable optimal dosing regimen for ampicillin divided by GA and PNA.

#### 9.8.1.5 Analysis of Surrogate Pharmacodynamic Endpoint

A simulation-based analysis was designed to determine the dose needed to provide exposure at the trough concentration above the MIC of either 2 mcg/mL or 8 mcg/mL for at least 90% of the participants. The final compartmental population PK model was used in these simulations.

#### 9.8.1.6 Interim Pharmacokinetic Analysis

No interim PK analysis was performed.

### 9.8.2 Determination of Sample Size

Due to the paucity of preliminary PK/PD data on the drugs under study, formal sample size calculations were not performed. Biological samples were scheduled to be processed for PK analysis after enrollment of approximately 64 infants for ampicillin.

## 9.9 Changes in the conduct of the Study or the Planned Analyses

Changes to the first version of the NICHD-2011-POP01 protocol are listed in Appendix 16.4.1. A second protocol amendment (protocol version 3.0) was finalized on November 28, 2012, after the completion of the last participant enrolled under ampicillin and is not included in the appendix.