# 8 STUDY OBJECTIVES

1. Characterize the PK of ampicillin from samples obtained in a PK study of ampicillin
2. Characterize the safety of ampicillin prescribed to infants per standard of care by their treating caregiver