# 6 INVESTIGATORS AND STUDY ADMINISTRATIVE STRUCTURE

## 6.1 Principal Investigators

Objective #1 includes participants enrolled under the NICHD-2011-POP01 study, which was a multicenter study with 9 enrolling sites in the United States that enrolled participants who received ampicillin per standard of care (SOC). A list of principal investigators and their affiliations, roles in the study, and curriculum vitae are provided in Appendix 16.1.4. The signatures of the sponsor’s responsible medical officer, medical monitor, and coordinating investigator for this study appear in Appendix 16.1.5.

## 6.2 Administrative Structure

The following is a list of organizations that were critical to the conduct of the study:

IND Sponsor and Principal Investigator | Daniel K Benjamin Jr., MD, PhD, MPH; Professor, Duke University Pediatrics; Duke Clinical Research Institute; ▬; Durham, NC 27715
Co-Investigator | Michael Cohen-Wolkowiez, MD, PhD; Assistant Professor, Duke University Pediatrics; Duke Clinical Research Institute; ▬; Durham, NC 27715
Funding Sponsor | Eunice Kennedy Shriver National Institute of Child Health and Human Development
Best Pharmaceuticals for Children Act (BPCA) Data Coordinating Center (DCC) | The EMMES Corporation; 401 N. Washington Street, Suite 700; Rockville, MD 20850
Medical Monitor | ▬▬▬▬▬; Chief Medical Officer; The EMMES Corporation; 401 N. Washington Street, Suite 700; Rockville, MD 20850
Pharmacokinetic Analysis | ▬▬▬▬▬; Division of Pharmacology and Drug Discovery; Schools of Medicine and Pharmacy and Pharmaceutical Sciences; University of California; San Diego, CA 92093; ▬▬▬▬▬; Division of Pharmacology and Drug Discovery; School of Medicine; University of California, San Diego; 9500 Gilman Drive, ▬; La Jolla, CA 92093
Safety Analysis | ▬▬▬▬▬; Associate Professor, Department of Pediatrics; Duke University Medical Center; Duke Clinical Research Institute; ▬; Durham, NC 27715; ▬▬▬▬▬; Assistant Professor, Department of Pediatrics; Department of Pediatrics; Duke University Medical Center; ▬; Durham, NC, 27710