# 15 REFERENCE LIST

1 Van den Hoogen A, Gerards LJ, Verboon-Maciolek MA, Fleer A, Krediet TG. Long-term trends in the epidemiology of neonatal sepsis and antibiotic susceptibility of causative agents. Neonatology. 2010;97:22–28 19571584
2 Stoll BJ, Hansen NI, Bell EF, Shankaran S, Laptook AR, Walsh MC, . Neonatal outcomes of extremely preterm infants from the NICHD Neonatal Research Network. Pediatrics. 2010;126:443–456.20732945
3 Clark RH, Bloom BT, Spitzer AR, Gerstmann DR. Reported medication use in the neonatal intensive care unit: data from a large national data set. Pediatrics. 2006 Jun;117:1979–87.16740839
4 Ampicillin package literature. http://dailymed.nlm.nih.gov/dailymed/search.cfm?labeltype=all&query=ampicillin (http://dailymed.nlm.nih.gov/dailymed/search.cfm?labeltype=%0ball&query=ampicillin). Accessed November 24, 2014.
5 Nahata MC, Vashi VI, Swanson RN, Messig MA, Chung M. Pharmacokinetics of ampicillin and sulbactam in pediatric patients. Antimicrob Agents Chemother. 1999;43:1225–9.10223940
6 Ginsburg CM, McCracken GH Jr, Thomas ML, Clahsen J. Comparative pharmacokinetics of amoxicillin and ampicillin in infants and children. Pediatrics. 1979 Nov;64(5):627–31.492836
7 Ripa S, Ferrante L, Prenna M. Pharmacokinetics of sulbactam/ampicillin in humans after intravenous and intramuscular injection. Chemotherapy. 1990;36:185–92.2338029
8 Sjövall J, Alván G, Huitfeldt B. Intra- and inter-individual variation in pharmacokinetics of intravenously infused amoxycillin and ampicillin to elderly volunteers. Br J Clin Pharmacol. 1986;21:171–81.3954933
9 Eshelman FN, Spyker DA. Pharmacokinetics of amoxicillin and ampicillin: crossover study of the effect of food. Antimicrob Agents Chemother. 1978;14:539–43.363052
10 Chmel H, Emmanuel G, Lie T, Anderson L, Ireland J. A prospective, double-blind, randomized study comparing the efficacy and safety of low-dose ciprofloxacin with ampicillin in the treatment of bronchitis. Diagn Microbiol Infect Dis. 1990 Mar–Apr;13(2):149–51.2196150
11 Young TE and Mangum B. Neofax A manual of drugs used in neonatal care. 24th edition. Montvale, NJ: Thompson Reuters; 2011.
12 Kaplan JM, McCracken GH Jr, Horton LJ, Thomas ML, Davis N. Pharmacologic studies in neonates given large dosages of ampicillin. J Pediatr. 1974 Apr;84(4):571–7.4600568
13 Boe RW, Williams CPS, Bennet JV, Oliver TK Jr. Serum levels of methicillin and ampicillin in newborn and premature infants in relation to postnatal age. Pediatrics. 1967 Feb;39(2):194–201.6017957
14 Axline SG, Yaffe SJ, Simon HJ. Clinical pharmacology of antimicrobials in premature infants: II. Ampicillin, methicillin, oxcillin, neomycin, and colistin. Pediatrics. 1967 Jan;39(1):97–107.6016648
15 Metsvaht T, Ilmoja ML, Parm U, Maipuu L, Merila M, Lutsar I. Comparison of ampicillin plus gentamicin vs. penicillin plus gentamicin in empiric treatment of neonates at risk of early onset sepsis. Acta Paediatr. 2010;99:665–72. Epub 2010 Jan 20.20096030
16 Shaffer CL, Davey AM, Ransom JL. Ampicillin-induced neurotoxicity in very-low-birth-weight neonates. Ann Pharmacother. 1998;32:482–484.9562146
17 Barrons RW, Murray KM, Richey RM. Populations at risk for penicillin-induced seizures. Ann Pharmacother. 1992 Jan;26(1):26–9.1606340
18 Sheffield MJ, Lambert DK, Henry E, Christensen RD. Effect of ampicillin on the bleeding time of neonatal intensive care patients. J Perinatol. 2010 Aug;30:527–30. Epub 2009 Dec 3120043011
19 Wade KC, Wu D, Kaufman DA, Ward RM, Benjamin DK Jr, Sullivan JE, Ramey N, Jayaraman B, Hoppu K, Adamson PC, Gastonguay MR, Barrett JS; National Institute of Child Health and Development Pediatric Pharmacology Research Unit Network. Population pharmacokinetics of fluconazole in young infants. Antimicrob Agents Chemother. 2008 Nov;52(11):4043–9. doi: 10.1128/AAC.00569-08. Epub 2008 Sep 22.18809946
20 Cohen-Wolkowiez M, Ouellet D, Smith PB, James LP, Ross A, Sullivan JE, Walsh MC, Zadell A, Newman N, White NR, Kashuba AD, Benjamin DK Jr. Population pharmacokinetics of metronidazole evaluated using scavenged samples from preterm infants. Antimicrob Agents Chemother. 2012 Apr;56(4):1828–37 22252819
21 Cohen-Wolkowiez M, Benjamin DK Jr, Ross A, James LP, Sullivan JE, Walsh MC, Zadell A, Newman N, White NR, Kashuba AD, Ouellet D. Population pharmacokinetics of piperacillin using scavenged samples from preterm infants. Ther Drug Monit. 2012 Jun;34(3):312–9 22569355
22 Clinical and Laboratory Standards Instititue (CLSI). Performance Standards for Antimicrobial Disk Susceptibility Tests. 11th ed. (M02–A11). Wayne, PA: Clinical and Laboratory Standards Instititute; 2012.
23 Arcara K and Tschudy M (eds). The Harriet Lane Handbook: A Manual For Pediatric House Officers. 19th ed. Philadelphia, PA: Mosby Elsevier, 2011.
24 Taketomo CK, Hodding JH, Kraus DM. Pediatric and Neonatal Dosage Handbook. 19th ed. Hudson, OH: Lexicomp; 2012.
25 Smith PB, Cohen-Wolkowiez M, Castro LM, Poindexter B, Bidegain M, Weitkamp JH, . Population pharmacokinetics of meropenem in plasma and cerebrospinal fluid of infants with suspected or complicated intra-abdominal infections. Pediatric Infect Dis J. 2011;30(10):844–9. Epub 2011/08/11. doi: 10.1097/INF.0b013e31822e8b0b. PubMed PMID: 21829139; PubMed Central PMCID: PMC3173561.21829139