# 14 TABLES REFERRED TO BUT NOT INCLUDED IN THE TEXT

## 14.1 Study Disposition, Baseline Participant Characteristics, and Protocol Deviation Summary Tables (NICHD-2011-POP01)

14.1.1.1 Participant Accounting and Final Study Disposition by Age Group All Enrolled Ampicillin Participants
14.1.1.2 Participant Enrollment by Site and Age Group All Enrolled Ampicillin Participants
14.1.2 Demographic, Baseline, and Medical History Characteristics by Age Group All Enrolled Ampicillin Participants
14.1.3.1 Summary of Participant Specific Protocol Deviations by Site All Enrolled Ampicillin Participants
14.1.3.2 Number of Participants with Protocol Deviations by Site All Enrolled Ampicillin Participants
14.1.3.3 Reasons Indicated for Participant Specific Protocol Deviations Across All Sites All Enrolled Ampicillin Participants

## 14.2 Dosing and PK Collection Summary Tables (NICHD-2011-POP01)

14.2.1 Fresh Plasma Sampling Dose Summary by Age Group All Enrolled Ampicillin Participants
14.2.2 PK Sample Summary by Age Group All Enrolled Ampicillin Participants
14.2.3 Summary of the PK Concentration (ng/mL) by Sampling Window and Age Group All Enrolled Ampicillin Participants
14.2.4 Concomitant Medications by Age Group Safety Ampicillin Population
14.2.5 Clinical Laboratory Test Summary by Age Group All Enrolled Ampicillin Participants

## 14.3 Safety Tables (NICHD-2011-POP01)

14.3.1.1 Summary of Adverse Events by Age Group Safety Ampicillin Population

Table 14.1.1.1 Participant Accounting and Final Study Disposition by Age Group All Enrolled Ampicillin Participants

| Post-Natal Age ≤7 Days | | Post-Natal Age 8-28 Days | | Total (N=75)
| GA ≤34 Weeks (N=21) | GA >34 Weeks (N=27) | GA ≤34 Weeks (N=8) | GA >34 Weeks (N=19) | Total (N=75)
Number of Enrolled Participants | 21 | 27 | 8 | 19 | 75
Number of Participants with At Least 1 Available Plasma Sample | 21 | 27 | 8 | 19 | 75
Number of Participants with Research-Only Samples | 6 | 14 | 3 | 5 | 28
Number of Participants Enrolled Under Multiple DOIs at Time of Data Lock | 1 | 2 | 3 | 1 | 7
Number of Participants Enrolled Under Each DOI
Clindamycin | 1 | 1 | 3 | 1 | 6
Metoclopramide | 0 | 1 | 0 | 0 | 1

Note: One participant was enrolled with 30 days PNA.

Table 14.1.1.2 Participant Enrollment by Site and Age Group All Enrolled Ampicillin Participants

Site | Post-Natal Age ≤7 Days | | Post-Natal Age 8-28 Days | | Total (N=75)
Site | GA ≤34 Weeks (N=21) | GA >34 Weeks (N=27) | GA ≤34 Weeks (N=8) | GA >34 Weeks (N=19) | Total (N=75)
▬▬▬▬▬ | 0 | 0 | 0 | 1 (100.0%) | 1 (100.0%)
▬▬▬▬▬ | 0 | 0 | 0 | 1 (100.0%) | 1 (100.0%)
▬▬▬▬▬ | 1 (50.0%) | 0 | 0 | 1 (50.0%) | 2 (100.0%)
▬▬▬▬▬ | 14 (33.3%) | 16 (38.1%) | 4 (9.5%) | 8 (19.0%) | 42 (100.0%)
▬▬▬▬▬ | 0 | 0 | 0 | 2 (100.0%) | 2 (100.0%)
▬▬▬▬▬ | 0 | 4 (50.0%) | 0 | 4 (50.0%) | 8 (100.0%)
▬▬▬▬▬ | 3 (33.3%) | 2 (22.2%) | 3 (33.3%) | 1 (11.1%) | 9 (100.0%)
▬▬▬▬▬ | 2 (40.0%) | 1 (20.0%) | 1 (20.0%) | 1 (20.0%) | 5 (100.0%)
▬▬▬▬▬ | 1 (20.0%) | 4 (80.0%) | 0 | 0 | 5 (100.0%)

Note: N’s in the column header represent number of Ampicillin enrolled participants in each age group for all sites.

The denominator is the total number of participants at the site.

Table 14.1.2 Demographic, Baseline, and Medical History Characteristics by Age Group All Enrolled Ampicillin Participants

| Post-Natal Age ≤7 Days | | Post-Natal Age 8-28 Days | | Total (N=75)
| GA ≤34 Weeks (N=21) | GA >34 Weeks (N=27) | GA ≤34 Weeks (N=8) | GA >34 Weeks (N=19) | Total (N=75)
Post-Natal Age at Day of First Plasma PK Sample (Days)
N | 21 | 27 | 8 | 19 | 75
Mean (SD) | 2.7 (2.4) | 2.9 (2.7) | 14.8 (4.2) | 14.4 (6.5) | 7.0 (6.9)
Median (Min-Max) | 2.0 (0.0 - 7.0) | 2.0 (0.0 - 7.0) | 14.5 (9.0 - 21.0) | 13.0 (8.0 - 30.0) | 6.0 (0.0 - 30.0)
Gestational Age (Weeks)
N | 21 | 27 | 8 | 19 | 75
Mean (SD) | 30.3 (3.4) | 38.2 (2.0) | 27.8 (3.4) | 38.3 (1.7) | 34.9 (5.0)
Median (Min-Max) | 32.3 (24.3 - 34.0) | 38.0 (34.4 - 41.4) | 26.5 (25.0 - 33.9) | 38.6 (35.3 - 41.3) | 36.1 (24.3 - 41.4)
Gender
Male | 9 (42.9%) | 18 (66.7%) | 4 (50.0%) | 9 (47.4%) | 40 (53.3%)
Female | 12 (57.1%) | 9 (33.3%) | 4 (50.0%) | 10 (52.6%) | 35 (46.7%)
Ethnicity
Hispanic or Latino | 3 (14.3%) | 6 (22.2%) | 2 (25.0%) | 3 (15.8%) | 14 (18.7%)
Not Hispanic or Latino | 18 (85.7%) | 19 (70.4%) | 5 (62.5%) | 15 (78.9%) | 57 (76.0%)
Not reported | 0 | 2 (7.4%) | 1 (12.5%) | 1 (5.3%) | 4 (5.3%)
Race
Black or African American | 4 (19.0%) | 3 (11.1%) | 3 (37.5%) | 2 (10.5%) | 12 (16.0%)
White or Caucasian | 16 (76.2%) | 23 (85.2%) | 4 (50.0%) | 15 (78.9%) | 58 (77.3%)
Not reported | 0 | 0 | 0 | 1 (5.3%) | 1 (1.3%)
Other | 1 (4.8%) | 0 | 1 (12.5%) | 1 (5.3%) | 3 (4.0%)
More Than 1 Race | 0 | 1 (3.7%) | 0 | 0 | 1 (1.3%)
Weight at first sample collection (gm)
N | 21 | 27 | 8 | 19 | 75
Mean (SD) | 1407 (580.1) | 3208 (739.2) | 1088 (399.7) | 3181 (768.5) | 2471 (1139
Median (Min-Max) | 1460 (460.0 - 2600) | 3385 (2001 - 5420) | 1110 (660.0 - 1874) | 3000 (1900 - 4450) | 2500 (460.0 - 5420)
Height/length at time of first sample collection (cm)
N | 21 | 27 | 8 | 19 | 75
Mean (SD) | 38.7 (6.3) | 49.6 (5.0) | 35.2 (3.9) | 48.7 (3.6) | 44.8 (7.5)
Median (Min-Max) | 40.0 (23.5 - 48.0) | 49.5 (39.0 - 67.2) | 35.5 (30.0 - 41.0) | 48.0 (41.5 - 55.0) | 47.0 (23.5 - 67.2)
Diagnosis of cystic fibrosis
Yes | 0 | 1 (3.7%) | 0 | 0 | 1 (1.3%)
No | 21 (100.0%) | 26 (96.3%) | 8 (100.0%) | 19 (100.0%) | 74 (98.7%)
Diagnosis of congenital heart disease
Yes | 0 | 0 | 1 (12.5%) | 1 (5.3%) | 2 (2.7%)
No | 21 (100.0%) | 27 (100.0%) | 7 (87.5%) | 18 (94.7%) | 73 (97.3%)
Extracorporeal Life Support
No | 21 (100.0%) | 27 (100.0%) | 8 (100.0%) | 19 (100.0%) | 75 (100.0%)

Table 14.1.3.1 Summary of Participant Specific Protocol Deviations by Site All Enrolled Ampicillin Participants

Site | Informed Consent/Assent | Protocol Procedure/Assessment | Other | Total
Total | 8 | 1 | 3 | 12
▬▬▬▬▬ | 0 | 0 | 1 | 1
▬▬▬▬▬ | 2 | 0 | 0 | 2
▬▬▬▬▬ | 0 | 1 | 2 | 3
▬▬▬▬▬ | 6 | 0 | 0 | 6

Table 14.1.3.2 Number of Participants with Protocol Deviations by Site All Enrolled Ampicillin Participants

Site | Informed Consent | Protocol Procedure/Assessment | Other | Total Participants with Deviations
Total | 5 (6.7%) | 1 (1.3%) | 3 (4.0%) | 9 (12.0%)
▬▬▬▬▬ | 0 | 0 | 1 (50.0%) | 1 (50.0%)
▬▬▬▬▬ | 2 (25.0%) | 0 | 0 | 2 (25.0%)
▬▬▬▬▬ | 0 | 1 (11.1%) | 2 (22.2%) | 3 (33.3%)
▬▬▬▬▬ | 3 (60.0%) | 0 | 0 | 3 (60.0%)

Note: Denominator is the number of participants enrolled at each site or total. Includes all deviations for participants enrolled under Ampicillin.

Table 14.1.3.3.1 Reasons Indicated for Participant Specific Protocol Deviations Across All Sites All Enrolled Ampicillin Participants

All Sites (N=75) | Research staff/clinic error | | Other | | Total
Deviation Category | # of Participants | # of Deviations | # of Participants | # of Deviations | # of Participants | # of Deviations
Total | 6 | 9 | 4 | 4 | 10 | 13
Informed consent/assent | 2 | 2 | 2 | 2 | 5 | 8
Informed consent/assent | 3 | 6 | 2 | 2 | 5 | 8
Protocol procedure/assessment | 1 | 1 | 2 | 2 | 2 | 2
Other | 3 | 3 | 0 | 0 | 3 | 3

Note: N=Number of participants. Includes all deviations for participants enrolled under Ampicillin.

Table 14.1.3.3.2 Indicated for Participant Specific Protocol Deviations by Site All Enrolled Ampicillin Participants Reasons

▬▬▬▬▬ (N=42) | Research staff/clinic error | | Other | | Total
Deviation Category | # of Participants | # of Deviations | # of Participants | # of Deviations | # of Participants | # of Deviations
Total | 0 | 0 | 1 | 1 | 1 | 1
Protocol procedure/assessment | 1 | 1 | 1 | 1 | 1 | 1

▬▬▬▬▬ (N=2) | Research staff/clinic error | | Other | | Total
Deviation Category | # of Participants | # of Deviations | # of Participants | # of Deviations | # of Participants | # of Deviations
Total | 1 | 1 | 0 | 0 | 1 | 1
Other | 1 | 1 | 0 | 0 | 1 | 1

▬▬▬▬▬ (N=8) | Research staff/clinic error | | Other | | Total
Deviation Category | # of Participants | # of Deviations | # of Participants | # of Deviations | # of Participants | # of Deviations
Total | 0 | 0 | 2 | 2 | 2 | 2
Informed consent/assent | 2 | 2 | 2 | 2 | 2 | 2

▬▬▬▬▬ (N=9) | Research staff/clinic error | | Other | | Total
Deviation Category | # of Participants | # of Deviations | # of Participants | # of Deviations | # of Participants | # of Deviations
Total | 2 | 2 | 1 | 1 | 3 | 3
Protocol procedure/assessment | 0 | 0 | 1 | 1 | 1 | 1
Other | 2 | 2 | 0 | 0 | 2 | 2

▬▬▬▬▬ (N=5) | Research staff/clinic error | | Other | | Total
Deviation Category | # of Participants | # of Deviations | # of Participants | # of Deviations | # of Participants | # of Deviations
Total | 3 | 6 | 0 | 0 | 3 | 6
Informed consent/assent | 3 | 6 | 0 | 0 | 3 | 6

Note: N=Number of participants at site. Includes all deviations for participants enrolled under Ampicillin.

Table 14.2.1 Fresh Plasma Sampling Dose Summary by Age Group All Enrolled Ampicillin Participants

| Post-Natal Age ≤7 Days | | Post-Natal Age 8-28 Days | | Total
| GA ≤34 Weeks | GA >34 Weeks | GA ≤34 Weeks | GA >34 Weeks | Total
Dose Summary
Number of Sampling Doses | 34 | 51 | 12 | 31 | 128
Average Number of Recorded Doses Per Participant | 5.9 | 7.6 | 8.6 | 9.3 | 7.7
Number of Sampling Doses Per Participant
1 | 9 (42.9%) | 7 (25.9%) | 5 (62.5%) | 9 (47.4%) | 30 (40.0%)
2 | 11 (52.4%) | 16 (59.3%) | 2 (25.0%) | 8 (42.1%) | 37 (49.3%)
3 | 1 (4.8%) | 4 (14.8%) | 1 (12.5%) | 2 (10.5%) | 8 (10.7%)
Dose Amount: All Sampling Doses (mg/kg)
N | 34 | 51 | 12 | 31 | 128
Mean (SD) | 98.6 (12.6) | 92.7 (14.9) | 79.3 (25.4) | 86.0 (15.2) | 91.4 (16.6)
Median (Min-Max) | 99.7 (50.0 - 128.6) | 100.0 (43.1 - 106.1) | 86.1 (7.8 - 100.0) | 92.1 (46.2 - 100.8) | 99.0 (7.8 - 128.6)
Dose Amount: Maximum Sampling Dose Per Participant (mg/kg)
N | 21 | 27 | 8 | 19 | 75
Mean (SD) | 98.7 (14.9) | 92.2 (15.9) | 78.6 (31.7) | 85.8 (15.1) | 90.9 (18.5)
Median (Min-Max) | 100.0 (50.0 - 128.6) | 100.0 (46.1 - 106.1) | 92.3 (7.8 - 100.0) | 87.5 (46.2 - 100.8) | 99.3 (7.8 - 128.6)
Dosing Frequency: All Sampling Doses
QID (6 hours) | 0 | 0 | 0 | 14 (45.2%) | 14 (10.9%)
TID (8 hours) | 4 (11.8%) | 27 (52.9%) | 0 | 11 (35.5%) | 42 (32.8%)
BID (12 hours) | 29 (85.3%) | 24 (47.1%) | 11 (91.7%) | 6 (19.4%) | 70 (54.7%)
QD (24 hours) | 1 (2.9%) | 0 | 1 (8.3%) | 0 | 2 (1.6%)
Administration Route: All Sampling Doses
IV - Intravenous | 34 (100.0%) | 51 (100.0%) | 12 (100.0%) | 30 (96.8%) | 127 (99.2%
IM - Intramuscular | 0 | 0 | 0 | 1 (3.2%) | 1 (0.8%)

Table 14.2.2 PK Sample Summary by Age Group All Enrolled Ampicillin Participants

| Post-Natal Age ≤7 Days | | Post-Natal Age 8-28 Days | | Total
| GA ≤34 Weeks | GA >34 Weeks | GA ≤34 Weeks | GA >34 Weeks | Total
Number PK Samples
Number of Available Fresh Plasma PK Samples | 46 | 60 | 16 | 38 | 160
Number of Non-Plasma PK Samples | 32 | 98 | 20 | 28 | 178
Number of Available Fresh Plasma PK Samples Per Participant
1 | 2 (9.5%) | 2 (7.4%) | 3 (37.5%) | 6 (31.6%) | 13 (17.3%)
2 | 15 (71.4%) | 19 (70.4%) | 2 (25.0%) | 9 (47.4%) | 45 (60.0%)
3 | 2 (9.5%) | 4 (14.8%) | 3 (37.5%) | 2 (10.5%) | 11 (14.7%)
4 | 2 (9.5%) | 2 (7.4%) | 0 | 2 (10.5%) | 6 (8.0%)
Number of Available Fresh Plasma PK Samples in Each Sampling Window
After IV Dose/Flush | 14 (30.4%) | 14 (23.3%) | 3 (18.8%) | 7 (18.4%) | 38 (23.8%)
1-4 Hours | 0 | 0 | 0 | 6 (15.8%) | 6 (3.8%)
2-5 Hours | 2 (4.3%) | 10 (16.7%) | 0 | 2 (5.3%) | 14 (8.8%)
2-8 Hours | 12 (26.1%) | 8 (13.3%) | 5 (31.3%) | 5 (13.2%) | 30 (18.8%)
3-12 Hours | 1 (2.2%) | 0 | 1 (6.3%) | 0 | 2 (1.3%)
Elimination: 24-36 Hours | 4 (8.7%) | 4 (6.7%) | 0 | 1 (2.6%) | 9 (5.6%)
Window 3: Pre-Dose | 3 (6.5%) | 5 (8.3%) | 1 (6.3%) | 1 (2.6%) | 10 (6.3%)
Drawn Before End of Flush | 1 (2.2%) | 2 (3.3%) | 0 | 1 (2.6%) | 4 (2.5%)
Out-of-Window | 9 (19.6%) | 17 (28.3%) | 6 (37.5%) | 15 (39.5%) | 47 (29.4%)
Time Until Frozen for Evaluable Fresh Plasma PK Samples (minutes)
N | 46 | 60 | 16 | 38 | 160
Mean (SD) | 35.1 (13.7) | 31.5 (11.3) | 35.4 (20.2) | 42.7 (38.0) | 35.6 (22.2)
Median (Min-Max) | 33.0 (15.0 - 77.0) | 27.0 (15.0 - 60.0) | 30.0 (16.0 - 80.0) | 31.0 (15.0 - 236.0) | 30.0 (15.0 - 236.0)
Samples with Freeze Time > 60 Minutes | 2 (4.3%) | 0 | 2 (12.5%) | 6 (15.8%) | 10 (6.3%)

Note: Sampling windows are presented in the CSR.

Table 14.2.3 Summary of the PK Concentration (ng/mL) by Sampling Window and Age Group All Enrolled Ampicillin Participants

| Post-Natal Age ≤7 Days | | Post-Natal Age 8-28 Days | | Total
| GA ≤34 Weeks | GA >34 Weeks | GA ≤34 Weeks | GA >34 Weeks | Total
After IV Dose/Flush
N | 14 | 14 | 3 | 7 | 38
Mean (SD) | 273.4 (130.6) | 241.0 (101.5) | 123.7 (76.7) | 210.3 (53.0) | 238.1 (109.8)
Median (Min-Max) | 304.9 (43.4 - 463.6) | 233.4 (23.6 - 387.9) | 125.7 (46.1 - 199.4) | 214.5 (125.3 - 278.8) | 233.4 (23.6 - 463.6)
1-4 Hours
N | 0 | 0 | 0 | 6 | 6
Mean (SD) | | | | 204.7 (283.0) | 204.7 (283.0)
Median (Min-Max) | | | | 118.8 (40.0 - 777.1) | 118.8 (40.0 - 777.1)
2-5 Hours
N | 2 | 10 | 0 | 2 | 14
Mean (SD) | 244.1 (130.1) | 151.2 (42.4) | | 122.9 (47.9) | 160.4 (63.9)
Median (Min-Max) | 244.1 (152.2 - 336.1) | 161.7 (99.3 - 238.8) | | 122.9 (89.0 - 156.8) | 157.4 (89.0 - 336.1)
2-8 Hours
N | 12 | 8 | 5 | 5 | 30
Mean (SD) | 175.4 (63.8) | 92.0 (39.4) | 177.0 (138.8) | 62.6 (20.3) | 134.6 (83.8)
Median (Min-Max) | 189.3 (23.5 - 254.1) | 84.4 (54.8 - 176.5) | 142.2 (35.6 - 402.5) | 58.0 (40.0 - 90.1) | 111.1 (23.5 - 402.5)
3-12 Hours
N | 1 | 0 | 1 | 0 | 2
Mean (SD) | 194.7 | | 17.4 | | 106.0 (125.4)
Median (Min-Max) | 194.7 | | 17.4 | | 106.0 (17.4 - 194.7)
Elimination: 24-36 Hours
N | 4 | 4 | 0 | 1 | 9
Mean (SD) | 8.7 (7.8) | 6.7 (12.6) | | 0.2 | 6.8 (9.5)
Median (Min-Max) | 8.9 (0.4 - 16.5) | 0.4 (0.3 - 25.6) | | 0.2 | 0.5 (0.2 - 25.6)
Pre-Dose
N | 3 | 5 | 1 | 1 | 10
Mean (SD) | 76.1 (37.1) | 25.2 (15.9) | 16.3 | 7.1 | 37.8 (33.9)
Median (Min-Max) | 86.0 (35.0 - 107.3) | 31.5 (6.6 - 42.7) | 16.3 | 7.1 | 33.2 (6.6 - 107.3)
Drawn Before End of Flush
N | 1 | 2 | 0 | 1 | 4
Mean (SD) | 104.6 | 196.4 (48.6) | | 199.6 | 174.2 (54.3)
Median (Min-Max) | 104.6 | 196.4 (162.0 - 230.8) | | 199.6 | 180.8 (104.6 - 230.8)
Out-of-Window
N | 9 | 17 | 6 | 15 | 47
Mean (SD) | 98.8 (71.1) | 60.8 (68.6) | 100.6 (78.7) | 48.5 (51.4) | 69.2 (66.8)
Median (Min-Max) | 119.7 (0.2 - 208.2) | 28.8 (0.1 - 273.0) | 102.3 (4.3 - 177.8) | 38.1 (0.4 - 209.7) | 43.0 (0.1 - 273.0)

Table 14.2.4 Concomitant Medications by Age Group Safety Ampicillin Population

No concomitant medications were reported.

Table 14.2.5 Clinical Laboratory Test Summary by Age Group All Enrolled Ampicillin Participants

| Post-Natal Age ≤7 Days | | Post-Natal Age 8-28 Days | | Total
| GA ≤34 Weeks | GA >34 Weeks | GA ≤34 Weeks | GA >34 Weeks | Total
Number of Participants with Lab Measures
Serum Creatinine | 21 (100.0%) | 19 (70.4%) | 4 (50.0%) | 13 (68.4%) | 57 (76.0%)
Albumin | 3 (14.3%) | 5 (18.5%) | 1 (12.5%) | 6 (31.6%) | 15 (20.0%)
AST | 3 (14.3%) | 3 (11.1%) | 1 (12.5%) | 4 (21.1%) | 11 (14.7%)
ALT | 3 (14.3%) | 3 (11.1%) | 1 (12.5%) | 4 (21.1%) | 11 (14.7%)
Direct Bilirubin | 13 (61.9%) | 7 (25.9%) | 2 (25.0%) | 6 (31.6%) | 28 (37.3%)
Total Bilirubin | 21 (100.0%) | 22 (81.5%) | 3 (37.5%) | 8 (42.1%) | 54 (72.0%)
Serum Creatine (mg/dL)
N | 24 | 24 | 7 | 15 | 70
Mean (SD) | 0.9 (0.4) | 0.5 (0.2) | 0.9 (0.3) | 0.4 (0.2) | 0.7 (0.3)
Median (Min-Max) | 0.8 (0.5 - 2.5) | 0.5 (0.2 - 1.0) | 0.8 (0.5 - 1.2) | 0.3 (0.2 - 0.8) | 0.6 (0.2 - 2.5)
Albumin (g/dL)
N | 3 | 5 | 1 | 7 | 16
Mean (SD) | 2.3 (0.3) | 3.2 (0.6) | 3.6 | 2.8 (0.5) | 2.9 (0.6)
Median (Min-Max) | 2.2 (2.0 - 2.6) | 3.4 (2.3 - 3.8) | 3.6 | 2.9 (2.0 - 3.6) | 2.9 (2.0 - 3.8)
AST (U/L)
N | 3 | 3 | 1 | 5 | 12
Mean (SD) | 30.7 (12.6) | 21.7 (3.1) | 24.0 | 59.6 (58.1) | 39.9 (39.7)
Median (Min-Max) | 29.0 (19.0 - 44.0) | 21.0 (19.0 - 25.0) | 24.0 | 44.0 (13.0 - 161.0) | 27.0 (13.0 - 161.0)
ALT (U/L)
N | 3 | 3 | 1 | 5 | 12
Mean (SD) | 7.0 (1.7) | 8.0 (2.0) | 11.0 | 18.8 (8.0) | 12.5 (7.5)
Median (Min-Max) | 8.0 (5.0 - 8.0) | 8.0 (6.0 - 10.0) | 11.0 | 19.0 (8.0 - 30.0) | 9.0 (5.0 - 30)
Direct Bilirubin (mg/dL)
N | 15 | 8 | 2 | 7 | 32
Mean (SD) | 0.4 (0.3) | 0.5 (0.6) | 0.2 (0.3) | 0.4 (0.3) | 0.4 (0.4)
Median (Min-Max) | 0.4 (0.0 - 0.9) | 0.3 (0.1 - 2.1) | 0.2 (0.0 - 0.4) | 0.4 (0.0 - 0.7) | 0.4 (0.0 - 2.1)
Total Bilirubin (mg/dL)
N | 26 | 25 | 3 | 9 | 63
Mean (SD) | 5.7 (1.6) | 7.7 (3.7) | 3.1 (1.2) | 5.0 (5.2) | 6.2 (3.4)
Median (Min-Max) | 6.0 (1.5 - 8.1) | 7.3 (3.3 - 17.6) | 2.8 (2.1 - 4.4) | 2.6 (0.9 - 16.3) | 6.0 (0.9 - 17.6)

Note: Only includes the closest clinical laboratory test to start of each sampling dose associated with available fresh plasma PK samples. Labs collected within 24 hours of dose start.

Table 14.3.1.1 Summary of Adverse Events by Age Group Safety Ampicillin Population

No AEs or SAEs were reported.