# 5 ETHICS

## 5.1 Institutional Review Board (IRB)

Institutional Review Board (IRB) approval of the protocol and waiver of informed consent for the NICHD-2012-AMP01 study overall was obtained prior to receiving data from any of the involved studies. As this is a data analysis study, no participants were enrolled under this protocol.

For the NICHD-2011-POP01 study, Institutional Review Board (IRB) approval of the protocol and, any protocol amendments, informed consent/assents (as indicated) and all other forms of subject information related to the study, was obtained prior to authorization of any study procedures. Detailed IRB information is provided in Appendix 16.1.3. Participants were enrolled under this protocol.

## 5.2 Ethical Conduct of the Study

This study was conducted in accordance with the protocol, ethical principles originating from the Declaration of Helsinki and current GCP and in compliance with local regulatory requirements and 21 CFR 312.

## 5.3 Patient Information, Consent, and Assent

All participants included in the data analysis of this study were children (under the age of 21 years). No participants were enrolled under this protocol. No informed consent form was used for this data analysis protocol. A waiver of informed consent was obtained from the IRB. Please see Appendix 16.1.3.

Informed consent process was followed by the Investigators according to the original studies. The investigator or designated representative explained the nature of the study to the patient and the patient’s parents or legal guardian, to the extent compatible with the patient’s understanding, and answered all questions regarding this study. Prior to any study related screening procedures being performed on the patient, the informed consent (parental permission) statement was signed and dated by the patient’s parent or legal guardian and by the person who administered the informed consent. A copy of the informed consent form (ICF) was given to the patient, or the patient’s parents or legal guardian, and the original was placed in the patient’s medical record. In addition, the Health Insurance Portability and Accountability Act (HIPAA) statement was reviewed, signed, and dated by the patient’s parent or legal guardian. A sample ICF for the NICHD-2011-POP01 study is provided in Appendix 16.1.3.