# 16 APPENDICES

16.1 Study Information
  16.1.1 Protocol and Protocol Amendments (NICHD-2012-AMP01)
  16.1.2 Sample Case Report Form (NICHD-2011-POP01)
  16.1.3 Institutional Review Boards (IRBs) and Participant Consents and Information (NICHD-2011-POP01)
  16.1.4 Description of Investigators (NICHD-2011-POP01)
  16.1.5 CSR Signature Page
  16.1.6 Listing of Batch Numbers by Patient
  16.1.7 Randomization Scheme and Codes
  16.1.8 Audit Certificates
  16.1.9 Statistical Analysis Plan (NICDH-2011-POP01)
  16.1.10 Documentation of Inter-laboratory Standardization Methods and Quality Assurance Procedures
  16.1.11 Publications Based on the Study
  16.1.12 Important Publications Referenced in the Report
  16.1.13 Written Request
16.2 Participant Data Listings (NICHD-2011-POP01)
16.3 Case Report Forms for Participants with SAEs
16.4 Miscellaneous
  16.4.1 Protocol for Study NICHD-2011-POP01
  16.4.2 PPRU Study Report
  16.4.3 Pediatrix Database Report
    16.4.3.1 Ampicillin Safety in Hospitalized Infants (Analysis of the Pediatrix Database) – Report
    16.4.3.2 Description of Pediatrix Datasets
    16.4.3.3 Pediatrix Data Dictionary
  16.4.4 Pharmacokinetic Report - NICHD-2011-POP01
    16.4.4.1 PK Report
    16.4.4.2 PK Tables
    16.4.4.3 PK Figures
    16.4.4.4 PK Listings
    16.4.4.5 NONMEM Control Stream
  16.4.5 Sample Bioanalysis Report
16.5 Datasets and Define.pdf
  16.5.1 Description of Datasets
  16.5.2 NICHD-2011-POP01 Dataset
  16.5.3 PPRU Dataset
  16.5.4 NICHD-2011-POP01 Pharmacokinetic Dataset
  16.5.5 Data Dictionaries

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/20222