# 4 LIST OF ABBREVIATIONS

Abbreviation: Definition
AE: Adverse Event
ALT: Alanine Aminotransferase
AST: Aspartate Aminotransferase
AUC: Area Under the Concentration Time Curve
AUCss: Area Under the Curve, Steady State
AVM: Arteriovenous Malformations
BPCA: Best Pharmaceuticals for Children Act
BMI: Body Mass Index
BUN: Blood Urea Nitrogen
CDC: Centers for Disease Control and Prevention
CFR: Code of Federal Regulations
CI: Confidence Interval
CL: Clearance
CL/F: Oral Apparent Clearance
Cmax: Maximum Concentration
CRCL: Creatinine Clearance
CRF: Case Report Form
CT: Computerized Tomography
CV: Coefficient of Variance
DCC: Data Coordinating Center
DCF: Data Collection Form
DCRI: Duke Clinical Research Institute
DOI: Drug of Interest
eCRF: Electronic Case Report Form
EDC: Electronic Data Capture
EEG: Electroencephalogram
EGFR: Estimated glomerular filtration rate
ER: Extended Release
FDA: Food and Drug Administration
FFM: Fat Free Mass
GCP: Good Clinical Practice
HIPAA: Health Insurance Portability and Accountability Act
ICF: Informed Consent Form
ICH: International Council on Harmonisation
ICMJE: International Committee of Medical Journal Editors
IDES: Internet Data Entry System
IND: Investigational New Drug
IRB/IEC: Institutional Review Board/Independent Ethics Committee
IV: Intravenous
KA: Absorption Rate Constant
Kg: Kilogram
LAR: Legally Authorized Representative
MedDRA: Medical Dictionary for Regulatory Activities
mcg: Microgram
mg: Milligram
MHD: 10-Monohydroxy Metabolite
mL: Milliliter
MOP: Manual of Procedures
N: Number (typically refers to participants)
NDA: New Drug Application
NICHD: National Institute of Child Health and Human Development
NIH: National Institutes of Health
PD: Pharmacodynamics
PI: Principal Investigator(s)
PK: Pharmacokinetics
PO: Oral
PTN: Pediatric Trials Network
SAE: Serious Adverse Events
SUSARs: Suspected Unexpected Serious Adverse Reactions
t_1/2_: Half-life
T_max_: Time to reach maximum concentration
V: Volume of Distribution
Vss/F: Oral apparent volume of distribution at steady state
WHO: World Health Organization