# 2 SYNOPSIS

Funding Sponsor: The Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD) in compliance with Best Pharmaceuticals for Children Act (BPCA)

IND Sponsor: Christoph P. Hornik, MD, PhD, MPH, Duke University Medical Center, Duke Clinical Research Institute

Study Drug: Levetiracetam

Title of Study: Pharmacokinetics of Anti-epileptic Drugs in Obese Children

Protocol ID: NICHD-2015-AED01

Principal Investigator:

Kanecia Zimmerman, MD, MPH, Associate Professor of Pediatrics, Duke Clinical Research Institute, Duke University

Study Center(s): 10 clinical sites in the Pediatric Trials Network (PTN)

Publication: None.

Studied Period:; Date of Inclusion of First Participant: January 19, 2017; Date of Completion of Last Participant: September 3, 2019 | Phase of Development: N/A (PK and Safety)

Objectives:

Primary: Determine the pharmacokinetics (PK) of selected anti-epileptic drugs (levetiracetam, valproic acid, topiramate, and oxcarbazepine) in obese children and adolescents.

Secondary: Evaluate safety of selected anti-epileptic drugs in obese children and adolescents.

Methodology: The PK and safety analyses in this report include levetiracetam data from NICHD-2015-AED01, “Pharmacokinetics of Anti-epileptic Drugs in Obese Children” (AED01), a multi-center, prospective, open-label, PK and safety study of anti-epileptic drugs in obese children age 2 to less than 18 years of age who receive drugs per standard of care, as prescribed by a treating clinician. The AED01 study enrolled participants under multiple drugs of interest, including levetiracetam.

Inclusion Criteria:

1. 2 years to < 18 years at the time of enrollment
2. BMI ≥ 95th percentile for age and sex, based on Centers for Disease Control and Prevention (CDC) recommendations
3. Documented informed consent/HIPAA from the parent/legal guardian and assent (if applicable)
4. Receiving ≥ 1 of the study drugs per local standard of care

Exclusion Criteria:

1. Known pregnancy as determined via interview or test results, if available

Test Product, Dose and Mode of Administration, Batch Number:

In the AED01 study, participants received standard of care levetiracetam, provided by the sites’ local pharmacies, according to their standard operating procedures. The study protocol did not specify the brand or batch numbers to be used. Levetiracetam immediate release in the following formulations were accepted for the study: tablet, oral solution, oral suspension, syrup, and all oral formulations.

Number of Participants: A total of 117 participants were enrolled into the AED01 study where 42 participants received levetiracetam.

Duration of Treatment:

Up to 14 days (up to 7 days of screening and 7 days of PK sampling)

Criteria for Evaluation:

Efficacy: The efficacy of levetiracetam was not evaluated in this study.

Pharmacokinetics:

The following primary PK parameters were assessed for levetiracetam through a population PK analysis:

1. Area under the curve (AUC_ss_)
2. Maximum concentration (Cmax)
3. Time to reach maximum concentration (Tmax)
4. Oral apparent volume of distribution (Vss/F)
5. Half-life (t_1/2_)
6. Oral apparent clearance (CL/F)
7. Absorption rate constant (ka)

Safety:

Adverse events (AEs) and serious adverse events (SAEs) related to study procedures, and serious, unexpected, suspected adverse reactions of levetiracetam were collected.

Statistical Methods:

Descriptive statistics, such as number of observations, mean, median, standard deviation, standard error, minimum, and maximum, are presented by age group for continuous variables (such as age, weight, etc.). Other descriptive statistics such as counts, proportions, and/or percentages are presented by age group to summarize discrete variables (such as race, sex, etc.).

A population analysis on the PK samples of levetiracetam collected under protocols AED01 and NICHD-2011-POP01, “Pharmacokinetics of Understudied Drugs Administered to Children per Standard of Care” (POP01) was performed. A total of 341 plasma concentrations from 164 participants who were 2 years to <18 years of age were available to develop the population PK model. Half of the plasma concentrations were collected after oral administration. A 1-compartment model-(ADVAN2 TRANS2) using the software for nonlinear mixed effects modeling (NONMEM version 7.4) and the First Order Conditional Estimation method with interaction best fit the data. The relationship between body size descriptors (body weight, lean body mass (LBM), fat free mass (FFM), and normal fat mass NFM) and PK parameters (clearance and volume of distribution) was explored using a fixed exponent allometric relationship. The model with allometric scaling based on the best body size descriptor was selected as the base model. A univariable covariate screen was performed for potential associations with PK parameters. Fat free mass (FFM) and estimated glomerular filtration rate (EGFR) were identified as significant covariates for clearance. The final irreducible model included the following relationships:

K A_i_ ( h^− 1^ ) = 2.12 (1)

C L_i_ ( L ⋅ h^− 1^ ) = 4.42 * ( (F F M_i_)/(56.1 k g) )^0.75^ * ( (C R C L_i_)/(121.4) )^0.425^ (2)

V_i_ ( L ) = 47.2 * ( (F F M_i_)/(56.1 k g) )^1^ (3)

F_i_ = 1.0 (4)

where FFM is fat free mass (kg); EGFR is estimated glomerular filtration rate (mL/min/1.73m^2^), as computed using the bedside Schwartz equation. KA is the absorption rate constant, and F is bioavailability.

The between-subject variability (CV%) for clearance (CL) and volume of distribution (V) were 38% and 40%, respectively.

Monte Carlo simulation was performed to identify the optimal dose for obese children using the PK parameter estimates from the final model. The participants from AED01 and POP01 study with estimated normal renal function (EGFR> 80 mL/min/1.73m^2^) were used in the simulation. A variety of dosing regimens including weight-based dosing regimens and weight-tiered dosing regimens were evaluated for initial dose and maximum label recommended dose of levetiracetam oral solution and tablet by age and weight group. One hundred runs of simulations were performed for each dose regimen. Levetiracetam exposure parameters including steady state maximum concentration (C_max,ss_) and steady state minimum concentration (C_min,ss_) were calculated for each participant. The simulated levetiracetam exposures in nonobese children and adolescents after labeled doses and the reported levetiracetam exposures in adults after labeled doses were used to guide dose optimization for levetiracetam in obese children and adolescents. Recommended dosing based on this process of dose optimization are listed in the table below:

Formulation | Age (years) | Obese status | Weight (kg) | Low dose | Medium dose | High dose | Dose frequency (hours)
Oral solution | 2–<4 | Nonobese and obese | 10–20 | 24 mg/kg/day | 48 mg/kg/day | 72 mg/kg/day | 8
Oral solution | 4–<16 | Obese | >20–40 | 20 mg/kg/day | 40 mg/kg/day | 60 mg/kg/day | 12
Oral solution | 4–<16 | Obese | >40–75 | 16 mg/kg/day | 32 mg/kg/day | 48 mg/kg/day | 12
Oral solution | 4–<16 | Obese | >75 | 14 mg/kg/day | 28 mg/kg/day | 42 mg/kg/day | 12
Tablet | 4–<16 | Obese | >20–40 | 500 mg/day | 1000 mg/day | 1500 mg/day | 12
Tablet | 4–<16 | Obese | >40–75 | 750 mg/day | 1500 mg/day | 2250 mg/day | 12
Tablet | 4–<16 | Obese | >75 | 1000 mg/day | 2000 mg/day | 3000 mg/day | 12

Conclusions

The PK of levetiracetam in children was well characterized with a 1-compartment population PK model. After accounting for size-based differences using fat free mass, estimated glomerular filtration rate, as computed using the bedside Scwartz equation, was associated with clearance of levetiracetam. A weight-based dosing regimen is recommended for levetiracetam oral solution dosing in 2 to <4 years. Weight-tiered dosing regimens are recommended for levetiracetam oral solution dosing and tablet dosing in obese 4 to <16 years.

Date of the Report: January 21, 2022