# 13 DISCUSSION AND OVERALL CONCLUSIONS

The PK of levetiracetam in children was well characterized with a 1-compartment population PK model. After accounting for size-based differences using fat free mass, estimated glomerular filtration rate was associated with clearance of levetiracetam. A weight-based dosing regimen is recommended for levetiracetam oral solution dosing in 2 to <4 years. Weight-tiered dosing regimens are recommended for levetiracetam oral solution dosing and tablet dosing in obese 4 to <16 years. Levetiracetam was well tolerated in the study participants.