# 12 SAFETY EVALUATION

## 12.1 Extent of Exposure

For this study, safety assessments began at the time of initial study-specific procedures (e.g. blood draws for safety or PK). The safety population is noted in Section 11.1. Adverse events (AEs) were assessed through 1 hour after last biological study sample collection and SAEs were assessed through study completion. All AEs were coded using MedDRA version 23.0.

## 12.2 Adverse Events

### 12.2.1 Brief Summary of Adverse Events

There was only one (2%) reported AE (generalized tonic-clonic seizure) in the 42 levetiracetam participants in the safety population. The severity of the AE was moderate and the event was reported as unrelated to study drug. The AE was reported as an SAE due to the initial or prolonged hospitalization.

### 12.2.2 Display of Adverse Events

Adverse Event (AE) and SAE data are presented in Table 12-1 given only one AE occurred among levetiracetam participants.

Table 12-1 Adverse Events and Serious Adverse Events

Participant ID | Age Group | Preferred Term | System Organ Class | Event Date | Resolution Date | Outcome | Severity | Related to Study Drug | Action Taken | SAE, Event Associated with
▬ | 12 – <18 years | Generalized tonic-clonic seizure | Nervous system disorders | ▬ | ▬ | Recovered/resolved | Moderate | No | Dose increased | Initial or prolonged hospitalization

### 12.2.3 Listing of Adverse Events by Participant

A listing of all AEs for levetiracetam participants is presented in Table 12-1.

### 12.2.4 Analysis and Discussion of Adverse Events

Only one AE, generalized tonic-clonic seizure, was reported in the levetiracetam group. It was of moderate severity and unrelated to study drug (Table 12-1).

## 12.3 Deaths, Other Serious Adverse Events, and Other Significant Adverse Events

### 12.3.1 Brief Summary of Deaths, Other SAEs, and Other Significant Adverse Events

No deaths were reported. One SAE (generalized tonic-clonic seizure) was reported in 42 participants. It was associated with initial or prolonged hospitalization and was unrelated to study drug. No levetiracetam participants withdrew from the study due to an AE.

### 12.3.2 Narratives of Deaths, Other Serious Adverse Events, and Certain Other Significant Adverse Events

There was only one SAE reported. A narrative of that SAE is included in Section 14.5. No deaths were reported.

### 12.3.3 Analysis and Discussion of Deaths, Other Serious Adverse Events, and Other Significant Adverse Events

No deaths were reported. A total of 1 participant experienced 1 SAE, which was an episode of generalized tonic-clonic seizure and was classified as moderate in severity and unrelated to study drug.

## 12.4 Outcomes of Special Interest

Outcomes of special interest were not investigated in this study.

## 12.5 Clinical Laboratory Evaluation

### 12.5.1 Brief Summary of Clinical Laboratory Measurements

Laboratory values of interest were recorded for all participants, when available, and if collected within the 7 days prior to the baseline period. If no standard of care laboratory results were available within the 7 days prior to the baseline period, a blood sample was obtained for completion of laboratory tests. Results for the study were obtained and recorded once during the study period, any time after consent was obtained. If multiple standard of care laboratory test results were available within the 7 days prior to the baseline period, the results obtained closest to the start of the first PK sample were used in the analysis.

Laboratory measurements were summarized in tables by age group with N, mean, standard deviation, median, minimum and maximum values, and as box plots. Each box plot displays the number available (N), mean, and median numerically below the graph.

The clinical laboratory measurements are presented in Table 14.3.6 and Figure 14.1.1.

### 12.5.2 Listing of Individual Laboratory Measurements by Participant

A listing of laboratory measurements by participant is included in Section 16.2.

### 12.5.3 Evaluation of Each Laboratory Parameter

The median value of baseline laboratory measurements were as follows: albumin was 3.7 g/dL (range 2.4–5.3 g/dL), alanine aminotransferase (ALT) was 23 U/L (range 6–344 U/L), aspartate aminotransferase (AST) was 31 U/L (range 10–119 U/L); blood urea nitrogen was 10 mg/dL (range 1–57 mg/dL); creatinine was 0.4 mg/dL (range 0.2–3.9 mg/dL); total protein was 6.9 g/dL (4.5–9.5 g/dL).

#### 12.5.3.1 Laboratory Values Over Time

Laboratory values over time were not investigated in this study.

## 12.6 Concomitant Medications

All concomitant medications of interest were reported if administered in the 7 days prior to administration of the first study dose until the final PK sample. A summary of concomitant medications of interest by age group is provided in Table 14.3.7. Eleven (27%) participants in the PK population reported taking at least one concomitant medications of interest: 4 (10%) reported taking oxcarbazepine; 3 (7%) reported valproic acid; 2 (5%) reported topiramate; 2 (5%) reported phenobarbital, respectively; 1 (2%) reported ketorolac; 1 (2%) reported phenytoin, respectively.

## 12.7 Safety Conclusions

Only one AE generalized tonic-clonic seizure event was reported and was not related to study drug. The AE was also reported as an SAE due to initial or prolonged hospitalization.