# 11 EFFICACY AND PHARMACOKINETIC EVALUATION

## 11.1 Data Sets Analyzed

A total of 42 participants received levetiracetam (safety population). Forty-one [41 (98%)] among them contributed at least 1 PK sample (PK population): 14 in 2 to <6 years, 14 in 6 to <12 years, and 13 in 12 to <18 years age groups. Thirty-six [36 (86%)] participants contributed at least 3 PK samples with 12 in each age group.

## 11.2 Demographic and Other Baseline Characteristics

Table 14.1.7 provides demographic and baseline characteristics by age group for the levetiracetam PK population. Median age was 8.7 years (range 2.1–17.9). Twenty-two (54%) participants were male, 19 (46%) were of White/Caucasian race, 13 (32%) were Black or African American, 5 (12%) reported more than 1 race, and 4 (10%) were unknown or not reported. Twelve (29%) participants reported Hispanic ethnicity. The standardized height and weight percentages were calculated by adjusting for the appropriate population, age- and sex-specific levels for the normal population provided by 2000 CDC growth charts. Median baseline weight was 42.7 kg (range 13.8–124.2 kg) with median weight percentile of 95.8% (range 34.2–99.85%). Median baseline height was 127 cm (range 75–179 cm) with median height percentile of 37.2% (range <0.1–98.7%). Median baseline BMI percentile was 98.5% (95.2 to >99.9%). Median baseline waist and hip circumferences were 75.5 cm (range 33.0–137.2 cm) and 82.4 cm (range 38.1–134.6 cm), respectively. Median baseline waist-to-hip ratio was 0.9 (range 0.8–1.2).

Baseline medical history is presented in Table 14.1.8 by MedDRA system (version 23.0) organ class and preferred term. The five most common medical conditions included: 15 (37%) participants with a history of seizure, 8 (20%) with epilepsy, 5 (12%) with tracheostomy, 5 (12%) with developmental delay, and 4 (10%) with hydrocephalus.

## 11.3 Efficacy Results and Tabulations of Individual Subject Data

There were no planned efficacy analyses as part of this study.

### 11.3.1 Tabulation of Individual Response Data

Individual participant data can be found in the Data Listings of Section 16.2

### 11.3.2 Drug Dose, Drug Concentration, and Relationships to Response

Dose summary by age group is presented in Table 14.3.9. Participants received levetiracetam for an average of 3 days while on study, and on average received 3 doses between the dose administered closest in time prior to the first PK sample until the final PK sample. The median of the participants’ mean administered dose was 17.2 mg/kg (range 4.8–66.7 mg/kg).

### 11.3.3 Drug-Drug and Drug-Disease Interactions

Potential drug-drug and drug-disease interactions were not investigated in this study.

### 11.3.4 By-Subject Displays

Listings by participant are presented in Section 16.2.

## 11.4 PK Analysis

Fat free mass (FFM) and EGFR were identified as significant covariates for CL. The final irreducible model included the following relationships:

K A_i_ ( h^− 1^ ) = 2.12 (1)

C L_i_ ( L ⋅ h^− 1^ ) = 4.42 * ( (F F M_i_)/(56.1 k g) )^0.75^ * ( (E G F R_i_)/(121.4) )^0.425^ (2)

V_i_ ( L ) = 47.2 * ( (F F M_i_)/(56.1 k g) )^1^ (3)

F_i_ = 1.0 (4)

Where FFM is fat free mass (kg); EGFR is estimated glomerular filtration rate (mL/min/1.73m2), as computed using the beside Schwartz equation. [10] KA is the absorption rate constant, F is bioavailability, V is volume of distribution, and CL is clearance. It is important to note that our analysis is fundamentally linked to a surrogate glomerular filtration rate estimate (i.e., EGFR computed using the bedside Schwartz equation) as opposed to ‘true’ glomerular filtration rate. Therefore, the utility of our model is to inform levetiracetam dosing in children with obesity is contingent on EGFR values computed using the bedside Schwartz equation.

The between-subject variability (CV%) for clearance (CL) and volume of distribution (V) were 38% and 40%, respectively. The median (range) post-hoc PK parameters are shown in Table 11-1.

Table 11-1 Summary of individual Empirical Bayesian Post-hoc parameter estimates by weight group in participants ≥2 years of age. ^a,b^

| Nonobese | | | | Obese
Parameters | Underweight (N= 8) | Normal weight (N= 37) | Overweight (N=9) | Total nonobese (N=54) | Class I obesity (N=72) | Class II obesity (N=28) | Class III obesity (N=10) | Total obese (N=110)
Age (years) | 13.45 (3.80–17.70) | 7.71 (2.13–20.48) | 9.10 (2.34–17.71) | 11.09 (2.13–20.48) | 9.89 (2.11–19.68) | 7.97 (2.34–17.80) | 13.87 (4.98–18.60) | 9.70 (2.11–19.68)
EGFR (mL/min/1.73 m^2^) | 128.17 (81.13–181.08) | 121.63 (11.16–422.30) | 164.00 (80.60–266.50) | 125.70 (11.16–422.30) | 123.35 (23.51–404.21) | 102.50 (8.35–194.75)^*^ | 118.06 (47.82–246.00) | 120.22 (8.35–404.21)
CL (L/h) | 2.90 (1.66–4.61) | 2.33 (0.47–8.63) | 3.37 (1.74–4.56) | 2.57 (0.47–8.63) | 2.58 (0.25–15.17) | 2.15 (0.34–5.14) | 3.59 (0.45–6.71) | 2.65 (0.25–15.17)
CL (L/h/kg) | 0.08 (0.06–0.13) | 0.09 (0.03–0.16) | 0.08 (0.03–0.14) | 0.09 (0.03–0.16) | 0.06 (0.02–0.19)^*^ | 0.05 (0.02–0.18)^*^ | 0.04 (0.02–0.07)^*^ | 0.06 (0.02–0.19)^*^
CL (L/h/70 kg) | 4.98 (3.65–7.00) | 4.68 (1.49–10.44) | 4.66 (1.98–7.13) | 4.77 (1.49–10.44) | 3.98 (0.86–13.55)^*^ | 3.51 (1.13–9.20)^*^ | 3.41 (1.54–4.56)^*^ | 3.71 (0.86–13.55)^*^
V (L) | 25.08 (10.44–33.81) | 16.87 (5.56–57.61) | 21.33 (9.35–50.16) | 20.21 (5.56–57.61) | 23.95 (5.31–97.08) | 22.87 (5.43–64.15) | 42.75 (4.40–73.58)^*^ | 24.24 (4.40–97.08)
V (L/kg) | 0.80 (0.64–0.88) | 0.67 (0.32–1.08) | 0.60 (0.44–0.74) | 0.67 (0.32–1.08) | 0.56 (0.20–1.11)^*^ | 0.53 (0.26–1.01)^*^ | 0.42 (0.32–0.75)^*^ | 0.55 (0.20–1.11)^*^
Half-life (h) | 6.59 (4.35–7.20) | 5.56 (2.13–13.93) | 5.11 (3.40–13.36) | 5.47 (2.13–13.93) | 5.99 (2.71–14.66) | 7.22 (3.01–11.30)^*^ | 7.41 (3.34–10.31)^*^ | 6.42 (2.71–14.66)^*^

a Values presented are medians (range). Weight group: Underweight: BMI<5^th^ percentile; Normal weight: BMI >=5^th^ percentile and BMI<85^th^ percentile: Overweight: BMI≥85^th^ percentile and BMI<95^th^ percentile; Nonobese: BMI<95^th^ percentile; Class I obesity: BMI ≥95^th^ percentile and BMI <120% of the 95^th^ percentile; Class II obesity: BMI ≥120% of the 95^th^ percentile and BMI <140% of the 95^th^ percentile: Class III obesity: BMI ≥140% of the 95^th^ percentile.

b Parameter estimates from each obesity and total obese class were compared to those from the total nonobese group.

* p-value<0.05 (Wilcoxon rank-sum test)

For children 2 to <4 years of age, simulated C_max,ss_ and C_min,ss_ after each intravenous and oral dosing regimen were comparable between nonobese and obese children (Table 11-2). Among the 5 oral solution dose regimens simulated for 2 to <4 years, a low dose of 24 mg/kg/day divided Q8h and a high dose of 72 mg/kg/day divided Q8h resulted in median C_max,ss_ and median C_min,ss_ most comparable to the corresponding values in adults after label doses. For children 4 to <16 years of age, obese children and adolescents had 25% higher median C_max,ss_ and 41% higher median C_min,ss_ after labeled doses of levetiracetam oral solution compared to their nonobese peers (Table 11-3). Using the proposed weight tiered doses for levetiracetam oral solution in Regimen #3, obese children and adolescents in all weight groups had comparable median C_max,ss_ and median C_min,ss_ to nonobese peers and adults after the corresponding label doses. For tablet dosing, the obese children and adolescents ages 4 to <16 years had 27% higher median C_max,ss_ and 19% higher median C_min,ss_ after label doses compared to their nonobese peers (Table 11-4). Adjusting tablet dosing for obese participants with weight of 40–75 kg (Regimen #1: 1000 mg/day and 3000 mg/day for low and high dose respectively) resulted in comparable C_max,ss_ and C_min,ss_ across weight groups in nonobese and obese participants. After the label tablet dose of levetiracetam, median C_max,ss_ and median C_min,ss_ in obese adolescents of ≥16 years were comparable to those in their nonobese peers (Table 11-5).

Table 11-2 Simulated levetiracetam exposure at steady state by obesity status after levetiracetam oral solution dose in children 2 to <4 years

| | | | Nonobese | | Obese
Dose Level | Regimen# | Dose (mg/kg/day) | Frequency (h) | C_max,ss_ (mcg/mL) | C_min,ss_ (mcg/mL) | C_max,ss_ (mcg/mL) | C_min,ss_ (mcg/mL)
Low | 1 | 20 | 12 | 14.7 (9.3–31.0) | 3.0 (0.0–18.8) | 16.4 (10.6–37.9) | 3.7 (0.1–24.0)
Low | 2 | 20 | 8 | 11.8 (6.0–30.7) | 4.5 (0.1–23.1) | 13.2 (7.0–39.4) | 5.2 (0.3–31.2)
Low | 3 | 20 | 6 | 10.4 (4.0–30.3) | 5.2 (0.0–25.1) | 11.9 (6.1–32.9) | 6.2 (0.8–26.7)
Low | 4 | 24 | 6 | 12.5 (4.8–36.4) | 6.2 (0.1–30.1) | 14.3 (7.3–39.5) | 7.4 (1.0–32.0)
Low | 5 | 24 | 8 | 14.2 (7.2–36.9) | 5.4 (0.1–27.7) | 15.8 (8.4–47.3) | 6.2 (0.4–37.5)
High | 1 | 60 | 12 | 44.0 (27.9–93.0) | 9.1 (0.1–56.3) | 49.3 (31.9–113.8) | 11.1 (0.3–72.1)
High | 2 | 60 | 8 | 35.4 (18.0–92.2) | 13.5 (0.2–69.3) | 39.6 (20.9–118.2) | 15.5 (1.0–93.7)
High | 3 | 60 | 6 | 31.1 (12.0–90.9) | 15.6 (0.1–75.2) | 35.7 (18.2–98.7) | 18.6 (2.5–80.0)
High | 4 | 72 | 6 | 37.4 (14.4–109.1) | 18.7 (0.2–90.2) | 42.8 (21.8–118.4) | 22.3 (2.9–96.0)
High | 5 | 72 | 8 | 42.5 (21.7–110.6) | 16.2 (0.3–83.2) | 47.5 (25.1–141.8) | 18.7 (1.3–112.4)

Values presented are medians (range)

Table 11-3 Simulated levetiracetam exposure at steady state by obesity status after levetiracetam oral solution dose in children and adolescents 4 to <16 years

| | Dose ^a,b^ (mg/kg/day) | | | Nonobese | | Obese
Dose Level | Regimen# | Nonobese | Obese | Weight Group | C_max,ss_ (mcg/mL) | C_min,ss_ (mcg/mL) | C_max,ss_ (mcg/mL) | C_min,ss_ (mcg/mL)
Low | 0 (label dose) | 20 | 20 | All | 16.6 (9.4–50.5) | 4.6 (0.0–36.2) | 20.8 (10.0–71.1) | 6.5 (0.0–54.2)
Low | 1 | 20 | 24 | All | 16.4 (9.4–50.4) | 4.5 (0.0–36.0) | 16.4 (9.0–49.6) | 5.1 (0.0–37.8)
Low | 2 | 20 | 20 | < 40 kg | 16.2 (9.5–41.9) | 4.4 (0.0–28.7) | 17.7 (9.9–56.9) | 4.6 (0.0–40.5)
Low | 2 | 20 | 18 | 40–75 kg | 18.1 (11.3–42.0) | 5.7 (0.2–27.1) | 19.3 (10.4–46.4) | 6.4 (0.1–33.4)
Low | 2 | 20 | 16 | >75 kg | -^c^ | -^c^ | 20.0 (10.6–65.1) | 7.3 (0.1–49.0)
Low | 3 | 20 | 20 | < 40 kg | 16.1 (9.1–44.8) | 4.4 (0.0–30.4) | 17.8 (10.4–45.1) | 4.7 (0.1–30.2)
Low | 3 | 20 | 16 | 40–75 kg | 18.1 (11.2–34.7) | 6.0 (0.3–22.6) | 16.9 (9.8–42.7) | 5.3 (0.2–31.0)
Low | 3 | 20 | 14 | >75 kg | -^c^ | -^c^ | 17.4 (8.9–49.3) | 6.3 (0.1–35.7)
High | 0 (label dose) | 60 | 60 | All | 49.8 (28.3–151.6) | 13.9 (0.1–108.5) | 62.3 (29.9–213.4) | 19.6 (0.1–162.6)
High | 1 | 60 | 72 | All | 49.3 (28.3–151.1) | 13.5 (0.1–108.0) | 49.2 (26.9–148.8) | 15.3 (0.1–113.5)
High | 2 | 60 | 60 | < 40 kg | 48.2 (28.4–125.8) | 12.8 (0.1–84.8) | 53.1 (29.7–170.8) | 13.9 (0.1–121.5)
High | 2 | 60 | 54 | 40–75 kg | 54.2 (33.8–125.9) | 17.2 (0.7–81.4) | 57.1 (29.9–139.3) | 18.5 (0.2–100.2)
High | 2 | 60 | 48 | >75 kg | -^c^ | -^c^ | 59.1 (31.7–195.2) | 20.9 (0.4–147.1)
High | 3 | 60 | 60 | < 40 kg | 48.4 (27.3–134.3) | 13.1 (0.1–91.3) | 53.4 (31.3–135.3) | 14.0 (0.3–90.5)
High | 3 | 60 | 48 | 40–75 kg | 54.4 (33.6–104.1) | 17.9 (0.9–67.8) | 50.6 (29.4–128.0) | 15.8 (0.5–93.1)
High | 3 | 60 | 42 | >75 kg | -^c^ | -^c^ | 52.2 (26.6–148.0) | 19.0 (0.4–107.0)

a Dose frequency was 12 hours for all the regimens.

b All doses were based on total body weight except Regimen #1 for obese pediatric patients, which was based on fat free mass.

c A11 nonobese participants had total body weight <75 kg.

Values presented are medians (range).

Table 11-4 Simulated levetiracetam exposure at steady state by obesity status after levetiracetam tablet dose in children 4 to <16 years

| | Dose (mg/day)^a^ | | | Nonobese | | Obese
Dose Level | Regimen# | Nonobese | Obese | Weight group | C_max,ss_ (mcg/mL) | C_min,ss_ (mcg/mL) | C_max,ss_ (mcg/mL) | C_min,ss_ (mcg/mL)
Low | 0 (label dose) | 500 | 500 | 20.1–40 kg | 13.7 (6.7–41.3) | 3.9 (0.1–28.6) | 17.5 (8.5–51.5) | 4.6 (0.0–36.0)
Low | 0 (label dose) | 1000 | 1000 | >40 kg | 19.0 (11.0–43.2) | 5.9 (0.4–30.1) | 17.1 (6.9–65.4) | 5.8 (0.1–49.0)
Low | 1 | 500 | 500 | 20.1–40 kg | 13.7 (6.7–41.3) | 3.9 (0.1–28.6) | 17.5 (8.5–51.5) | 4.6 (0.0–36.0)
Low | 1 | 1000 | 750 | >40–75 kg | 19.0 (11.0–43.2) | 5.9 (0.4–30.1) | 15.3 (6.5–49.1) | 4.8 (0.1–36.7)
Low | 1 | 1000 | 1000 | >75 kg | -^b^ | -^b^ | 14.0 (6.9–36.8) | 5.2 (0.1–26.8)
High | 0 (label dose) | 1500 | 1500 | 20.1–40 kg | 41.2 (20.2–124.0) | 11.7 (0.2–85.7) | 52.5 (25.6–154.4) | 13.9 (0.1–107.9)
High | 0 (label dose) | 3000 | 3000 | >40 kg | 57.1 (33.1–129.5) | 17.7 (1.1–90.4) | 51.2 (20.8–196.2) | 17.3 (0.3–146.9)
High | 1 | 1500 | 1500 | 20.1–40 kg | 41.2 (20.2–124.0) | 11.7 (0.2–85.7) | 52.5 (25.6–154.4) | 13.9 (0.1–107.9)
High | 1 | 3000 | 2250 | >40–75 kg | 57.1 (33.1–129.5) | 17.7 (1.1–90.4) | 46.0 (19.4–147.1) | 14.5 (0.3–110.1)
High | 1 | 3000 | 3000 | >75 kg | -^b^ | -^b^ | 42.0 (20.8–110.5) | 15.7 (0.3–80.4)

a Dose frequency was 12 hours for all the regimens.

b All nonobese participants had total body weight <75 kg. Values presented are median (range).

Table 11-5 Simulated levetiracetam exposure at steady state by obesity status after levetiracetam tablet dose in adolescents ≥16 years

| | | Nonobese | | Obese
Dose Level | Regimen# | Dose^a^ (mg/day) | C_max,ss_ (mcg/mL) | C_min,ss_ (mcg/mL) | C_max,ss_ (mcg/mL) | C_min,ss_ (mcg/mL)
Low | 0 (label dose) | 1000 | 18.1 (6.9–51.7) | 6.3 (0.4–40.1) | 14.8 (6.5–37.4) | 5.8 (0.5–25.9)
High | 0 (label dose) | 3000 | 54.3 (20.6–155.0) | 18.8 (1.1–120.4) | 44.3 (19.6–112.2) | 17.3 (1.4–77.6)

a Dose frequency was 12 hours for all the regimens.

Values presented are median (range)

## 11.5 PK Conclusions

The PK of levetiracetam in children was well characterized with a 1-compartment population PK model. After accounting for size-based differences using fat free mass, estimated glomerular filtration rate was associated with clearance of levetiracetam. A weight-based dosing regimen is recommended for levetiracetam oral solution dosing in children 2 to <4 years (Table 11-6). Weight-tiered dosing regimens are recommended for levetiracetam oral solution and tablet dosing in obese children 4 to <16 years (Table 11-6).

Table 11-6 Dosing recommendations for levetiracetam in pediatric patients ages 2 to <4 years and obese pediatric patients ages 4 to <16 years

Formulation | Age (years) | Obese Status | Weight (kg) | Low Dose | Medium Dose | High Dose | Dose Frequency (hours)
Oral Solution | 2–<4 | Nonobese and obese | 10–20 | 24 mg/kg/day | 48 mg/kg/day | 72 mg/kg/day | 8
Oral Solution | 4–<16 | Obese | >20–40 | 20 mg/kg/day | 40 mg/kg/day | 60 mg/kg/day | 12
Oral Solution | 4–<16 | Obese | >40–75 | 16 mg/kg/day | 32 mg/kg/day | 48 mg/kg/day | 12
Oral Solution | 4–<16 | Obese | >75 | 14 mg/kg/day | 28 mg/kg/day | 42 mg/kg/day | 12
Tablet | 4–<16 | Obese | >20–40 | 500 mg/day | 1000 mg/day | 1500 mg/day | 12
Tablet | 4–<16 | Obese | >40–75 | 750 mg/day | 1500 mg/day | 2250 mg/day | 12
Tablet | 4–<16 | Obese | >75 | 1000 mg/day | 2000 mg/day | 3000 mg/day | 12