# 10 STUDY PARTICIPANTS

## 10.1 Disposition of Subjects

The AED01 protocol opened enrollment on December 8, 2016, and enrollment closed on October 10, 2019, with a total of 117 participants entered into the Electronic Data Capture (EDC) system. The first participant was enrolled on January 19, 2017, and the last participant completed the study on September 3, 2019.

### 10.1.1 Overall Study Population

A total of 117 participants were enrolled in the AED01 study where 116 (99%) received at least 1 dose of any study drug (safety population) and 116 (99%) contributed at least 1 fresh plasma PK sample (PK population). Participants could contribute to more than one DOI. There were 107 DOI entries with at least 3 fresh plasma PK samples in the 4 different DOIs: 36 to levetiracetam, 22 to valproic acid, 26 to topiramate and 23 to oxcarbazepine.

Among 117 enrolled participants, 104 (89%) completed the study, defined as providing at least 3 fresh plasma PK samples for any DOI, and 13 (11%) were early terminated for the following reasons: insufficient sampling (n=6), discharge (n=5), ineligibility (n=1), and consent withdrawn by parents/guardian (n=1). Table 14.1.1 provides overall participant disposition by age group. As presented in Table 14.1.2, participants were enrolled at 10 sites. The highest enrolling site enrolled 37 participants.

One participant ▬, receiving oxcarbazepine was excluded from all analyses due to concerns regarding the integrity of the data reported for the participant due to insufficient documentation available at the clinical site. The participant is presented in the summaries of overall study enrollment and participant disposition (Tables 14.1.1 and 14.1.2, and Listing 16.2.1).

### 10.1.2 Levetiracetam Study Population

A total of 42 participants received levetiracetam (safety population). Of the total, 41 (98%) contributed at least 1 PK sample (PK population): 14 in 2 to <6 years, 14 in 6 to <12 years, and 13 in 12 to <18 years age groups. Thirty-six [36 (86%)] participants contributed at least 3 PK samples with 12 in each age group.

Among 42 levetiracetam participants, 38 (90.5%) completed the study and 4 (9.5%) were terminated early for one of two reasons: insufficient sampling (n=2) and discharge (n=2). Table 14.1.3 provides levetiracetam participant disposition by age group. As presented in Table 14.1.4, levetiracetam participants were enrolled at 9 sites. The highest levetiracetam enrolling site enrolled 14 participants.

## 10.2 Protocol Deviations

A total of 38 protocol deviations occurred in 10 (24%) of the 42 levetiracetam participants (Table 14.1.5). Of these, 1 deviation was classified as inclusion/exclusion criteria deviation (in 1 [2%] participants); 2 classified as informed consent/assent process executed incorrectly (in 2 [5%] participants); 4 classified as procedural error (in 4 [10%] participants); and 3 classified as specimen collection error (in 3 [7%] participants). Only one deviation was reported per participant in the study, therefore the number of participants having any deviation was the same as the number of total deviations under the same deviation category and total in Table 14.1.5. Reasons cited for the deviations include (Table 14.1.6) research staff error (6 deviations), laboratory error (1 deviation), investigator decision (1 deviation), and participant unable to comply (2 deviations).

Two site-specific protocol deviations occurred at 2 sites for the following reasons: the Lab Requisition Form for the technician did not specify to put samples on ice and samples were transferred to a backup freezer due to a −80 °C freezer alarm occurrence. Details are provided in Table 10-1.

Table 10-1 Site-specific Protocol Deviations

Site | Date of Deviation | Deviation Category | Deviation Description | Deviation Reason | Resolution | Comments
University of North Carolina at Chapel Hill | 25JUL2018 | Other, −80 freezer alarm went off, samples were moved from Room1035 to Room 1019. | −80 freezer alarm went off and samples were moved quickly to the backup freezer | Other, −80 Freezer alarm went off and samples had to be moved. | Samples were moved to the Neonatal Freezer and all future will be stored in NF. | The samples were moved quickly and specimen were not compromised.
University of Texas Southwestern Medical Center Dallas | 11MAY2017 | Specimen collection error | Lab Requisition form for technician did not specify to put samples on ice | Other, SC error - did not specify on lab reacquisition sheet proper instructions | Lab reacquisition sheet was updated 08MAY2018--only first 3 participants affected

A complete list of deviations is provided in Listing 16.2.4.