# 9 INVESTIGATIONAL PLAN

## 9.1 Overall Study Design and Plan

The AED01 study was a multi-center, prospective, open-label, PK and safety study of antiepileptic drugs in obese children 2 to less than 18 years of age who received drugs per standard of care, as prescribed by a treating clinician. Levetiracetam was one of the drugs of interest in the AED01 study.

## 9.2 Schedule of Assessments

The AED01 protocol provided a standardized plan for study assessments that applied across all DOIs. In addition to demographic data, assessment data collected under this protocol included dosing, PK sampling, clinical laboratory assessments, and AEs related to study procedures. The annotated case report forms (CRFs) for these assessments are included in Section 16.1.2.1.

A schedule of study procedures and assessments is presented in Table 9-1.

Table 9-1 Schedule of Study Procedures and Assessments

Study Event/Day | Baseline/Day 0^1^ | Study Day 1– 7
Informed consent/assent | X
Medical history^2^ | X
Demographics | X
Concomitant medications of interest | X | X
Physical examination^3^ | X
Weight^4^ | X | X
Height^4^ | X | X
BMI | X | X
Waist: hip ratio^4^ | X | X
Laboratory evaluation | X | X
Study drug administration | | X
Documentation of oral intake^5^ | | X
PK samples^6^ | | X
AE/SAE | | X

1 Day 0 refers to time point prior to start of study drug but may be the same calendar date as day 1

2 Includes history of cardiac, hepatic, renal, or metabolic disease

3 Includes assessment for anasarca, peripheral edema, heart exam

4 Only needs to be performed once per study

5 Documentation of fasted or fed state

6 Final PK sample marks the end of study

## 9.3 Selection of Study Populations

Eligible participant’s ages 2 to < 18 years were identified through outpatient clinic schedules and inpatient admissions at each participating site and enrolled in these age three groups:

- Group 1: 2 to < 6 years
- Group 2: 6 to < 12 years
- Group 3: 12 to < 18 years

### 9.3.1 Inclusion Criteria

1. 2 years to < 18 years at the time of enrollment
2. BMI ≥ 95th percentile for age and sex, based on CDC recommendations [8]
3. Documented informed consent/HIPAA from the parent/legal guardian and assent (if applicable)
4. Receiving ≥ 1 of the study drugs per local standard of care

### 9.3.2 Exclusion Criteria

1. Known pregnancy as determined via interview or test results, if available

### 9.3.3 Removal of Participants from Therapy or Assessment

A participant’s parent/guardian was permitted to voluntarily discontinue participation in this study at any time. The participant’s parent/guardian was not obligated to state the reason for withdrawal. The reasons for withdrawal, or failure to provide a reason, were documented by the investigator on the completion/withdrawal section of the eCRF.

An investigator was permitted to withdraw a participant from the study due to an AE, whether serious or nonserious, and investigators were instructed to follow the applicable event until the clinical outcome from the AE was determined. Investigators were instructed to note the AE(s) on the appropriate eCRFs, and to follow the participant’s progress until the AE was resolved or considered stable. The medical monitor or study PI was to be notified if the AE may have related to overdose of study treatment; the package insert was to be consulted for details of any specific action(s) to be taken.

## 9.4 Stopping or Suspending the Study

The NICHD, the sponsor, the Data Monitoring Committee (DMC), and the principal investigator had the right to recommend termination of enrollment into 1 or more of the drugs of interest in this study. Enrollment to any remaining drug(s) in the study was permissible. Furthermore, the NICHD, the sponsor, or the DMC had the right to terminate the study at any time.

## 9.5 Treatments

### 9.5.1 Treatments Administered

Participants received levetiracetam as part of standard of care treatment.

### 9.5.2 Identity of Investigational Product

Levetiracetam was provided by the sites’ or participant’s local pharmacies, according to their standard operating procedures. The study protocol did not specify the brand or batch numbers to be used. Levetiracetam immediate release in the following formulations were accepted for the study: tablet, oral solution, oral suspension, syrup, and all oral formulations.

### 9.5.3 Method of Assigning Subjects to Treatment Groups

Drug selection, dosing and administration was per standard of care, at the discretion of the treating clinician.

### 9.5.4 Selection of Doses in the Study

Levetiracetam dosing was per standard of care at the discretion of the participant’s treating clinician.

### 9.5.5 Selection and Timing of Dose for Each Participant

Drug selection, dosing and administration was per standard of care at the discretion of the treating clinician.

### 9.5.6 Blinding

Not applicable.

### 9.5.7 Prior and Concomitant Therapy

All drugs and/or treatments were permitted while on study. The date, time, route, and dose of all drugs and concomitant medications of interest administered in the 7 days prior to administration of the first study dose until the final PK sample, were recorded. Concomitant medications collected for levetiracetam were ketorolac, valproic acid, topiramate, and oxcarbazepine. Phenytoin, and phenobarbital data were collected from the participants who received levetirecetam if they also received other DOIs. These concomitant medications of interest were identified based on literature evidence that these drugs could potentially influence the PK or pharmacodynamics of levetiracetam.

### 9.5.8 Treatment Compliance

Participants were administered levetiracetam as part of standard of care; therefore, treatment compliance was not monitored.

## 9.6 Pharmacokinetic and Safety Variables

### 9.6.1 Pharmacokinetic and Safety Measurements Assessed

PK variables were parameters estimated from the population PK analysis.

For all drugs of interests under AED01, AEs or SAEs related to study procedures (collection of biological samples for research purposes) and serious, unexpected, suspected adverse reactions of understudied drug of interest were reported.

Details regarding timing of variable assessment can be found in Table 9-1.

#### 9.6.1.1 Pharmacokinetic Measurements

Blood (approximately 0.3 mL) samples were collected for plasma concentration determinations according to recommended PK sampling collection windows as described in Table 9-2 below, depending on the dosing interval of levetiracetam. A maximum of 10 blood samples for PK analysis were obtained per participant. Elimination samples were only obtained from participants who were scheduled to discontinue the drug within 24 hours with no plans to resume in the following 48 hours, or if the participant had not had the drug of interest within the preceding 24 hours. The dosing intervals described in Table 9-2 were used for participants who received one or more of the study drugs using the same dosing interval.

Table 9-2 Optimal PK sampling collection windows

| Dosing interval (hours)
PK Sample # | q 8 hrs | q 12 hrs | q 24 hrs
1 | 15 minutes prior to dose | 15 minutes prior to dose | 15 minutes prior to dose
2 | 1–2 hr | 1–2 hr | 1–3 hr
3 | 2.5–4 hr | 2.5–4 hr | 3–6 hr
4 | 4.5–6 hr | 5–8 hr | 6–12 hr
5 | 6.5–8 hr | 8–10 hr | 12–18 hr
6 (elimination) | 32–40 hr | 48–60 hr | 48–72 hr

Every effort was made to collect a minimum of 3 PK samples for each participant. Collection of PK samples in patients was timed with collection for laboratory tests done per standard of care to minimize blood draws specifically for the study when possible. If it was impractical to collect all PK samples during the same dosing interval, samples may have been obtained at different dosing intervals. Drug concentrations in plasma were measured at a central laboratory using a validated HPLC/MS-MS assay (Validation Report FRO-R5259, dated 03/08/2016, Section 16.4.4). The chromatography system and mass spectrometer used for sample analysis were a Sciex 6500 system. The Phenomenex, Synergi 4μm Max-RP, (50 × 2.0 mm, 80 Å) column and gradient mobile phase (water containing 0.1% [v/v] formic acid; methanol: acetonitrile (50:50, v/v) containing 0.1% [v/v] formic acid) were used. Accuracy and precision as assessed using four determinations at theoretical levels 1.00, 3.00, 150, 750, and 37,500 ng/mL were within the FDA bioanalytical assay validation criteria (e.g., ±15%). The lower limit of quantification for levetiracetam was 1 ng/mL.

Participants who had at least 1 PK sample were included in the PK analysis, but participants with < 3 PK samples may have been replaced to ensure accurate characterization of drug PK. An evaluable participant had at least 3 PK samples.

#### 9.6.1.2 Safety Measurements – Adverse Events

Because the study drug was administered per standard of care, only AEs that met the criteria as defined in the protocol (Section 16.1.1) were reported in the data system. Adverse Events (AEs) related to study procedures (collection of biological samples for research purposes), serious adverse events (SAEs) and serious, unexpected, suspected adverse reactions (SUSARs) of the drug of interest were recorded in the data system.

An AE was defined as any untoward medical occurrence in humans, whether or not considered drug related which occurs during the conduct of a clinical trial. Suspected Adverse Reaction was defined as any AE for which there was a reasonable possibility that the drug caused the AE. A reasonable possibility implies that there was evidence that the drug caused the event.

Adverse Reaction was defined as any AE caused by the drug.

Unexpected Adverse Event was defined as any AE where the specificity or severity of which was not consistent with the package insert or investigational plan or informed consent.

An SAE or serious suspected adverse reaction or serious adverse reaction was determined by the investigator or sponsor as any event occurring before the end of the PK sampling period that resulted in any of the following outcomes:

1. Death
2. Medical events in which the study participant was, in the opinion of the investigator or sponsor, at immediate risk of death from the reaction as it occurred and required immediate intervention (e.g., anaphylaxis, hepatic failure)
3. Persistent or significant incapacity or substantial disruption of the ability to conduct normal life functions
4. Inpatient hospitalization or prolongation of existing hospitalization
5. Important medical event that may not have resulted in 1 of the above outcomes but jeopardized the health of the study participant or required medical or surgical intervention to prevent 1 of the outcomes listed in the above definition of serious event

##### Guidelines for Assessing Severity

The investigator used the following definitions when assessing severity of an AE:

- Mild: Participant was aware of symptoms or had minor findings, but tolerated them well and no or minimal intervention was required
- Moderate: Participant experienced enough symptoms or findings to require intervention
- Severe: Participant experienced symptoms or findings that required significant intervention

##### Guidelines for Determining Causality

The site investigators reported their assessment of causality of an AE to study drug by answering the following question: Is there a reasonable possibility that the study drug caused the event?

“Reasonable possibility” meaning that there was evidence to suggest a causal relationship between the drug and the adverse event.

An affirmative answer designated the event as a suspected adverse reaction.

## 9.7 Clinical Laboratory Evaluations

Clinical laboratory results of interest performed in the local laboratory at each site were recorded for all participants when available and if collected within the 7 days prior to the baseline period. If the clinical laboratory results were not available from the 7 days prior to the baseline period, then they were obtained and recorded once during the study period after consent was obtained. The clinical laboratory evaluations of interest included creatinine, blood urea nitrogen, total protein, albumin, aspartate aminotransferase, alanine aminotransferase.

## 9.8 Data Quality Assurance

DCC-designated clinical monitors verified that the clinical trial was conducted and data were generated, documented (recorded), and reported in compliance with the protocol, GCP, and the applicable regulatory requirements. Clinical monitoring reports were submitted to the principal investigator, PTN, and NIH/NICHD.

The DCC implemented quality control procedures beginning with the data entry system and generated data quality control checks that were run on the study data. Any missing data or data anomalies were communicated to the sites for prompt clarification and resolution.

## 9.9 Statistical Methods Planned in the Protocol and Determination of Sample Size

### 9.9.1 Statistical and Analytical Plans

As outlined in the Statistical Analysis Plan for AED01 (Section 16.1.9), descriptive statistics such as number of observations, mean, median, standard deviation, standard error, minimum, and maximum were presented by age group and drug for continuous variables (such as age, weight, etc.). Other descriptive statistics such as counts, proportions, and/or percentages were presented by age group and drug to summarize discrete variables (such as race, sex, etc.). The PK analysis plan is described in the Pharmacokinetic Data Analysis Plan (Section 16.4).

[underlined: Demographic and Baseline Characteristics]: The number of participants completed and discontinued early from study and the reasons for discontinuation were summarized. Demographic and baseline characteristics were also summarized. Variables included race, age, sex, and selected clinical variables recorded prior to initiation of study drug.

[underlined: Safety and Clinical Laboratory Analyses]: The number of SAEs were summarized overall, by severity, and by each Medical Dictionary for Regulatory Activities (MedDRA) system organ class and preferred term. Prior and concomitant medications were summarized by World Health Organization (WHO) drug class. Laboratory data, such as hematology and serum chemistry data, were tabulated by age cohort for each drug.

### 9.9.2 Pharmacokinetic (PK) Analysis Plan

PK parameters were estimated by a 1-compartment model-(ADVAN2 TRANS2) using the software for nonlinear mixed effects modeling (NONMEM version 7.4) and the First Order Conditional Estimation method with interaction best fit the data. The plasma concentrations-time profiles of each study drug were presented in table form by participant and cohort. The appropriate 1-compartmental pharmacokinetic parameters were computed including Cmin,ss; Cmax,ss; CL/F; andVss/F. PK parameters were summarized by age cohort. The influence of covariates on PK parameters were explored. If not enough samples were obtained per participant to allow for non-compartmental analysis, a population PK analysis approach was used. Results from the PK analysis were combined with data from other PK trials (e.g., pharmacokinetics of understudied drugs administered per standard of care NCT01431326 (https://clinicaltrials.gov/ct2/show/NCT01431326)) to determine the impact of obesity on drug disposition in children and adolescents.

### 9.9.3 Populations for Analyses

The primary population for PK analysis included participants who contributed 1 or more samples. Participants who received at least one dose of study drug were determined to be eligible for the safety analysis.

### 9.9.4 Determination of Sample Size

The sample size was based on the ability to describe the PK in obese children across a wide range of ages. Evaluable participants were defined as having at least 3 PK samples. A sample size of 24 evaluable participants provides adequate precision in the PK parameter estimates (i.e., clearance (CL)) that is dependent on the underlying variability of the parameter (see Table 9-3). For example, assuming an inter-individual coefficient of variance (CV%) of 40% in the population clearance CL parameter estimate, a sample size of 24 participants provides a margin of error of ±14% in the 95% confidence interval (CI) of the CL estimate. [9]

Table 9-3 Precision (95% CI Margin of error) Estimates with a Sample Size of N=24

PK Parameter CV% | 95% CI Margin of Error
40% | ± 14%
50% | ± 17%
60% | ± 21%
80% | ± 28%

## 9.10 Changes in the Conduct of the Study or Planned Analyses

### 9.10.1 Changes in Study Conduct

The AED01 protocol version 1.0 dated June 27, 2016, and protocol version 2.0 dated February 8, 2018, were both submitted to the master protocol’s IND 139,604 on April 25, 2018 (Serial No. A0000).

Updates from protocol version 1.0 to version 2.0 included: modified acceptable formulations for drugs and added a delayed release of valproic acid, modified maximum duration of study participation from [underlined: up to 11 days] to [underlined: up to 14 days], modified from [underlined: 4 days of PK sampling] to [underlined: 7 days of PK sampling], modified estimated study enrollment duration from [underlined: approximately 18 months] to [underlined: approximately 24 months], increased the window of when the baseline assessment can occur, added potential sampling route, specified language regarding when weight and height assessments can be taken, specified when results of interest could be collected, specified that only one PK sample was needed when a participant was on both levetiracetam and oxcarbazepine, specific minimum number (3) of PK samples requested, specified criteria for evaluable participants and modified concomitant medications.

Clarification of protocol v2.0 was provided to site investigators via numbered memoranda as follows:

#2018–05 dated May 31, 2018: Additional concomitant medication to record for valproic acid was instituted in response to the FDA public notice stating that estrogen-containing contraceptives may affect the clearance of valproate.

#2019–04 dated March 14, 2019: Levetiracetam cohorts were re-opened in order to augment PK parameter estimate precision, based on the comment FDA included in their written response dated 7/18/2018, that it was unlikely a sample size of 24 patients would be sufficient to characterize the PK profile of the drugs of interest. The levetiracetam enrollment target was increased from 24 to 36 to enroll 12 additional participant participants (4 per age cohort).

Protocol versions 1.0 and 2.0 and the above referenced numbered memoranda are provided in Section 16.1.1.1.

### 9.10.2 Changes in Planned Analyses

Per protocol, all concomitant medications would be coded using the WHO drug classification system. However, a code list of the protocol specified concomitant medication names or categories of interest was used instead of a free text data collection format. This approach results in a data format that is sufficient for the analysis purposes without further coding, and thus the concomitant medications were not be coded by the WHO drug classification system in the CSR.

Since there was only one AE reported in the levetiracetam participants, the AE was summarized in a listing. Summary tables were not provided in the CSR.

### 9.10.3 Changes in Planned Enrollment

Based on the comment FDA included in their written response dated 7/18/2018, that it was unlikely a sample size of 24 patients would be sufficient to characterize the PK profile of the drugs of interest, the levetiracetam enrollment target was increased from 24 to 36 to enroll 12 additional participant participants (4 per age cohort).