# 8 STUDY OBJECTIVES

To characterize the PK and safety of oral anti-epileptics (levetiracetam, valproic acid, topiramate, and oxcarbazepine) in obese children and adolescents.

## 8.1 Primary Outcome Measures

To characterize the PK of selected anti-epileptics, the following outcome measures were used:

a. Area under the curve (AUC_ss_)
b. Maximum concentration (Cmax)
c. Time to reach maximum concentration (Tmax)
d. Oral apparent volume of distribution (Vss/F)
e. Half-life (t_1/2_)
f. Oral apparent clearance (CL/F)
g. Absorption rate constant (ka)

## 8.2 Secondary Outcome Measures

To characterize the safety of selected anti-epileptics, the following outcome measure was used:

a. Serious adverse events