# 7 INTRODUCTION

## 7.1 NICHD-2015-AED01

In consultation with FDA and other stakeholders, the NIH prioritized pediatric seizures as a therapeutic area in need of further study under the BPCA, and identified levetiracetam as one of four drugs with critical gaps in pediatric labeling. In support of this BPCA priority, the study protocol NICHD-2015-AED01, entitled “Pharmacokinetics of Anti-epileptic Drugs in Obese Children,” (AED01) was developed with the primary objective of characterizing how obesity may influence the PK and safety of anti-epileptic drugs in children.

The study AED01 was developed as a master protocol and is a multi-center, prospective, open-label, PK and safety study of anti-epileptic drugs in obese children less than 18 years of age who receive drugs per standard of care, as prescribed by a treating clinician. The AED01 protocol (Section 16.1.1.1) enrolled participants under multiple drugs of interest including levetiracetam. Enrollments for levetiracetam were closed on August 30, 2019.

## 7.2 Study Rationale

Levetiracetam is an anti-epileptic increasingly used in children due to its rapid and near complete absorption after oral administration, absence of interaction with other drugs, and primary metabolism outside of the liver. [1, 2, 3] Multiple studies have confirmed the linear PK of levetiracetam and support its dosing in approved populations. [4, 5]

Although levetiracetam is FDA approved in children, existing studies support dosing in normal weight subjects. Investigators have not specifically evaluated the PK of levetiracetam in obese children or adults. However, in a population PK model derived from 24 pediatric subjects (ages 6 to 12), investigators demonstrated that levetiracetam clearance depends on body weight and that the relationship is linear with increased body weight associated with increased clearance. [5] Because levetiracetam is renally cleared, the relationship between body weight and clearance may reflect maturation of renal function with age. [2, 5] However, it is unclear if this relationship holds in the setting of obesity (defined as Body Mass Index [BMI] ≥ 95th percentile for age and sex based on the 2000 Centers for Disease Control (CDC) recommendations), given the need to adjust levetiracetam dosing in patients with renal dysfunction, and the imprecision associated with estimating creatinine clearance in obese patients. [2, 6, 7]

### 7.2.1 FDA Review of the AED01 Study under the BPCA Regulatory Pathway

A Type C meeting request was submitted to the Agency on April 25, 2018 concurrently with the IND application (IND 139,604) for the master protocol, to discuss the adequacy of the data collected under AED01 for the Agency’s use in negotiating updates to the Dosing and Clinical Pharmacology sections of the four off-patent product labels under the unique regulatory pathway established under 409I. The Agency’s July 18, 2018 written response was primarily concerned about whether concomitant medication data was being appropriately collected and whether sample size calculations were correct.

The sponsor’s response to FDA comments was submitted to the Agency on November 5, 2018, addressing the two concerns raised by the Agency. The sponsor clarified that all concomitant medications of interest taken 7 days prior to the first PK sampling dose until the final PK sample would be collected, and that the dose amount, route of administration, and start and end dates for concomitant medications would be collected. The concomitant medications of interest collected for each drug of interest (DOI) are listed in Appendix 2 of the protocol. For concomitant medications of interest that are relevant for other DOIs for the study (oxcarbazepine, valproic acid and topiramate), data were recorded regarding each dose received during study participation (7 days prior to first PK sample through last PK sample). For all other concomitant medications, overall start and end dates, and dosing regimens were recorded.

In response to the Agency’s concerns on sample size calculations, the sponsor clarified that the sample size of 8 participants per age group per study drug was based on published recommendations for deriving sample size in pediatric pharmacokinetic studies, and on estimates of coefficient of variation for anti-epileptic drugs among children of normal weight published in the literature and in New Drug Application (NDA) clinical pharmacology reports. A table with associated references was included in the sponsor’s response showing the coefficient of variation for anti-epileptic drugs of interest. The sponsor additionally noted that anti-epileptic-specific concentration data from both obese and non-obese participants collected in the NICHD-2011-POP01 study, “Pharmacokinetics of Understudied Drugs Administered per Standard of Care” (POP01) (NCT01431326 (https://clinicaltrials.gov/ct2/show/NCT01431326)) would be combined with the AED01 trial data to develop a robust population PK model.

## 7.3 Clinical Study Report (CSR)

The main objective of the data presented in this CSR is to characterize the PK and safety of oral levetiracetam in obese children and adolescents with the intent of improving pediatric labeling of levetiracetam under the unique regulatory pathway established by the BPCA.

### 7.3.1 Data Sources

The PK model was developed using data from two BPCA studies, AED01 and POP01. Data was used from the primary study, AED01, and augmented with POP01 data to produce more robust pharmacokinetic parameter estimates.

#### 7.3.1.1 NICHD-2015-AED01

AED01 is described above in Sections 7.1 and 7.2.

#### 7.3.1.2 NICHD-2011-POP01

POP01 was a prospective multi-center trial to characterize the PK of understudied drugs, including levetiracetam, administered by clinicians to children <21 years old per standard of care. The POP01 protocol (Section 16.1.1.2) enrolled participants under multiple drugs of interest, each of which were administered to children per standard of care. Only participants, both obese and non-obese, enrolled for levetiracetam as the drug of interest are included in the PK analyses.

### 7.3.2 Structure for this Clinical Study Report

Section 8 (Study Objectives), Section 9 (Investigational Plan), Section 10 (Participant Disposition), Section 12 (Safety), Section 13 (Discussion and Conclusions) and Section 14 (Tables and Figures) summarizes data from the AED01 levetiracetam cohort.

Section 11 (Efficacy and PK) of this report covers PK analysis of levetiracetam data from both AED01 and POP01 studies.

Section 16 Appendices are included as separate documents. PK datasets, data dictionary, codes, and output for the PK analysis are presented in Section 16.4. The raw datasets and data dictionary for the AED01 levetiracetam data are presented in Section 16.5.