# 6 INVESTIGATORS AND STUDY ADMINISTRATIVE STRUCTURE

The AED01 study was conducted under contract to the National Institute of Child Health and Human Development (NICHD) in accordance with Section 409I of the Public Health Service Act, also known as the Best Pharmaceuticals for Children Act (BPCA). This legislation mandates the National Institutes of Health (NIH) to prioritize therapeutic areas in critical need for pediatric labeling; to sponsor pediatric clinical trials; and to submit these data to FDA for consideration for labeling changes.

Under the BPCA, the NICHD awarded a contract to Duke University, which established the Pediatric Trials Network (PTN) through its Duke Clinical Research Institute (DCRI). The NICHD awarded a separate contract to The Emmes Company, LLC to serve as the BPCA Data Coordinating Center (DCC).

Data for the AED01 study were collected by 10 study sites in the PTN. Curricula vitae and FDA 1572 forms for the principal investigators (PIs) at the participating PTN study sites, which contributed data to the AED01 study, are provided in Section 16.1.4.1.

Signatures of the IND Sponsor, Study PI, the NICHD project officer, and the Emmes BPCA DCC PI are provided in Section 16.1.5.

IND Sponsor | Christoph P. Hornik, MD, PhD, MPH; Associate Professor, Department of Pediatrics; Duke University Medical Center; Duke Clinical Research Institute; Durham, NC 27701; ▬; ▬
Study Principal Investigator | Kanecia O. Zimmerman, MD, MPH; Associate Professor, Department of Pediatrics; Duke University Medical Center; Duke Clinical Research Institute; Durham, NC 27701; ▬; ▬
Medical Director | ▬; Medical Director; The Emmes Company, LLC; ▬; ▬; ▬; ▬
BPCA DCC Principal Investigator | ▬; The Emmes Company, LLC; ▬; ▬; ▬; ▬
NICHD Contract Officer Technical Representative | Perdita Taylor-Zapata, MD; National Institute of Health (NIH); National Institute of Child Health and Human Development (NICHD); ▬; ▬; ▬; ▬