# 15 REFERENCE LIST

1 Radtke RA. Pharmacokinetics of levetiracetam. Epilepsia 2001;42 Suppl 4: 24–7.
2 French J. Use of levetiracetam in special populations. Epilepsia 2001; 42: 40–3.11564125
3 Nicolas JM, Collart P, Gerin B, In vitro evaluation of potential drug interactions with levetiracetam, a new antiepileptic agent. Drug metabolism and disposition: the biological fate of chemicals 1999;27: 250–4.9929511
4 Pellock JM, Glauser TA, Bebin EM, Pharmacokinetic study of levetiracetam in children. Epilepsia 2001;42: 1574–9.11879369
5 Chhun S, Jullien V, Rey E, Dulac O, Chiron C, Pons G. Population pharmacokinetics of levetiracetam and dosing recommendation in children with epilepsy. Epilepsia 2009; 50: 1150–7.19175400
6 Hirsch LJ, Arif H, Buchsbaum R, Effect of age and comedication on levetiracetam pharmacokinetics and tolerability. Epilepsia 2007;48: 1351–9.17573925
7 Winter MA, Guhr KN, Berg GM. Impact of various body weights and serum creatinine concentrations on the bias and accuracy of the Cockcroft-Gault equation. Pharmacotherapy 2012; 32: 604–12.22576791
8 BMI Percentile Calculator for Child and Teen. Centers for Disease Control and Prevention. Division of Nutrition, Physical Activity and Obesity, National Center for Chronic Disease Prevention and Health Promotion. https://www.cdc.gov/healthyweight/bmi/calculator.html
9 Wang Y, Jadhav PR, Lala M, Gobburu JV. Clarification on precision criteria to derive sample size when designing pediatric pharmacokinetic studies. J Clin Pharmacol. Oct 2012;52(10):1601–1606.
10 Schwartz GJ, Work DF. Measurement and estimation of GFR in children and adolescents. Clin J Am Soc Nephrol. 2009;4(11):1832–1843.19820136