# 14 TABLES, FIGURES AND GRAPHS REFERRED TO BUT NOT INCLUDED IN THE TEXT

## 14.1 Demographic Data

Table Number | Population | Table Title / Summary
14.1.1 | All Enrolled Participants | Participant Accounting and Final Study Disposition by Age Group
14.1.2 | All Enrolled Participants | Participant Enrollment by Site and Age Group
14.1.3 | All Enrolled Levetiracetam Participants | Participant Accounting and Final Study Disposition by Age Group
14.1.4 | All Enrolled Levetiracetam Participants | Participant Enrollment by Site and Age Group
14.1.5 | All Enrolled Levetiracetam Participants | Summary of Participant-specific Protocol Deviations by Site
14.1.6 | All Enrolled Levetiracetam Participants | Summary of Participant-specific Protocol Deviations by Reason for Deviation
14.1.7 | Levetiracetam PK Population | Demographic and Baseline Characteristics by Age Group
14.1.8 | Levetiracetam PK Population | Summary of Medical History by System Organ Class, Preferred Term, and Age Group

## 14.2 Efficacy Data

No efficacy data was collected in the study.

## 14.3 Safety Data

Table Number | Population | Table Title / Summary
14.3.1; Refer to Table 12.1^1^ | Levetiracetam Safety Population | Summary of Adverse Events by Age Group
14.3.2; Refer to Table 12.1^1^ | Levetiracetam Safety Population | Adverse Events by System Organ Class, Preferred Term, and Age Group
14.3.3; Refer to Table 12.1^1^ | Levetiracetam Safety Population | Serious Adverse Events by System Organ Class, Preferred Term, and Age Group
14.3.4; Refer to Table 12.1^1^ | Levetiracetam Safety Population | Adverse Events by System Organ Class, Preferred Term, Severity, and Age Group
14.3.5; Refer to Table 12.1^1^ | Levetiracetam Safety Population | Adverse Events by System Organ Class, Preferred Term, Relationship to Study Drug, and Age Group
14.3.6 | Levetiracetam PK Population | Clinical Laboratory Evaluations by Age Group
14.3.7 | Levetiracetam PK Population | Summary of Concomitant Medications of Interest by Age Group
14.3.8 | Levetiracetam PK Population | Summary of Physical Examination Findings by Body System and Age Group
14.3.9 | Levetiracetam PK Population | Summary of Study Doses by Age Group
14.3.10 | Levetiracetam PK Population | Summary of PK Samples by Age Group

1 Tables 14.3.1–14.3.5 not provided given only one AE reported in levetiracetam cohort (See Table 12-1 in the text).

## 14.4 Figures

Figure Number | Population | Figure Title / Summary
14.4.1 | Levetiracetam PK Population | Box Plot of Clinical Laboratory Evaluations by Age Group
14.4.2 | Levetiracetam PK Population | Participant Profile Plots

## 14.5 Narratives of Deaths, Other Serious Adverse Events, and subjects who withdrew from the study as the result of an adverse event of any severity

Subject #: | ▬
Event: | Generalized Tonic-Clonic Seizure
Causal Relationship: | No
Action taken: | Dose Increased
Severity: | Moderate
Outcome: | Recovered/Resolved
Onset Date: | ▬
Resolution Date: | ▬

Summary of Event: Participant ▬ was 13-year-old multi-racial male who was consented for the NICHD PTN-AED01 study on ▬ and had the first dose of study medication (levetiracetam, 1750 mg BID) recorded on ▬ (protocol requirement to collect study medication information for up to seven days prior to enrollment). The other study medications besides levetiracetam that are part of this protocol include valproic acid, topiramate and oxcarbazepine. The participant was hospitalized for generalized tonic-clonic seizure on ▬. The participant recovered and the event resolved the next day on ▬.

Medical/Surgical History: arteriovenous malformation; abscess; hypertension; epilepsy with multiple seizure types namely generalized tonic-clonic, complex partial seizures and febrile seizures; post-operative nausea; vision abnormalities; multiple craniotomy for repair intracranial arteriovenous malformation; craniectomy for osteomyelitis; debridement for skin/subcutaneous tissue of muscle and bone on face; microsurgeries; and myringotomy with tubes insertion. Participant is allergic to vancomycin.

Present Illness: Two days (▬) days prior to being consented into this current study, the participant was admitted for possible scalp wound infection. The participant had a headache at least a few times a day lasting from 30 seconds to a few minutes. On ▬, the participant had a craniectomy for irrigation and debridement. Post-operatively, the participant was switched from TMP/SMX to ciprofloxacin due to past sensitivities. The participant consented to the Anti-epileptic study on ▬ and on the morning of ▬, while watching TV, had a generalized tonic-clonic seizure with loss of consciousness. The participant received two rescue breaths due to concern of absent breath sounds. The seizure lasted 2–3 minutes resolving after the participant received 2 mg Ativan. A CT Scan of the head was done which showed only postoperative changes but no acute changes except evidence of mild pneumocephalus. The participant was transferred from the pediatric general floor to the pediatric intensive care unit for closer monitoring. The participant’s antibiotic was switched from fluoroquinolone to moxifloxacin and will likely need to be on this new antibiotic for approximately three months.

As of ▬, the participant remained at baseline and no further investigation for the seizure such as EEG was needed. The participants anti-epileptic drug dose was increased in hopes to prevent further breakthrough seizures. It is noted that the past seizures appear to be related to the participants untreated AVM and then after treatment, to non-compliance with Keppra. To avoid the non-compliance, the mother is providing the medicine in her presence to avoid missing any doses. The participant was transferred to the pediatric ward in hemodynamically stable condition and the event is being considered resolved as of ▬.

The participant had no further seizures during the hospital stay and on ▬ was discharged with instructions for lab workup checking magnesium, phosphorus, potassium and sodium; increase maintenance dose of Keppra to 2 g BID; provide rescue medication to participant for seizures lasting longer than 5 minutes with Clonazepam 2 mg oral dissolving tablet or intranasal Versed 10 mg PRN.

Concomitant medications: lorazepam, clonidine, acetaminophen, ciprofloxacin, diazepam, ibuprofen, levetiracetam, ondansetron, oxycodone, polyethylene glycol, scopolamine, sennosides, and sodium chloride infusion.

Study Drug: Study drug levetiracetam was first recorded in the database on ▬ at 1750 mg BID. The participant received the same dose until ▬ where the morning dose was 500 mg and the evening dose was increased to 2000 mg. The last study dose was recorded on ▬ at a dose of 2000 mg BID.

Site investigator’s Assessment: The site investigator assessed this event as serious (hospitalization), moderate in severity and unrelated to the study drug.

DCC Medical Monitor’s assessment: The event of generalized clonic-tonic seizures was assessed as serious, expected (to underlying medical history) and unrelated to the study product or study intervention. The participant had history of various types of seizures and the current episodes of seizure etiology remains unknown however could have been potentially due to the surgery. The event is noted as resolved at the time of this report and does not meet the requirements of expedited reporting to the regulatory authorities.

Table 14.1.1 Participant Accounting and Final Study Disposition by Age Group All Enrolled Participants

| Age Group
| 2 – <6 Years (N = 36) | 6 – <12 Years (N = 41) | 12 – <18 Years ^6^ (N = 40) | Total (N = 117)
Participants Enrolled ^1^
Safety population ^2^ | 35 (97.2%) | 41 (100.0%) | 40 (100.0%) | 116 (99.1%)
PK population ^3^ | 35 (97.2%) | 41 (100.0%) | 40 (100.0%) | 116 (99.1%)
Participants with at least 3 PK samples | 32 (88.9%) | 33 (80.5%) | 38 (95.0%) | 103 (88.0%)
Participant Status
Completed study ^4^ | 33 (91.7%) | 33 (80.5%) | 38 (95.0%) | 104 (88.9%)
Early termination | 3 (8.3%) | 8 (19.5%) | 2 (5.0%) | 13 (11.1%)
Reasons for Early Termination
Consent withdrawn by parent / guardian | 0 | 1 (2.4%) | 0 | 1 (0.9%)
Discharge | 1 (2.8%) | 3 (7.3%) | 1 (2.5%) | 5 (4.3%)
Ineligibility | 0 | 1 (2.4%) | 0 | 1 (0.9%)
Insufficient sampling | 2 (5.6%) | 3 (7.3%) | 1 (2.5%) | 6 (5.1%)
Participants Enrolled by Drug of Interest ^5^
Levetiracetam | 14 | 14 | 14 | 42
Valproic Acid | 6 | 11 | 10 | 27
Topiramate | 8 | 11 | 11 | 30
Oxcarbazepine | 10 | 9 | 9 | 28
Participants with ≥ 3 PK Samples by Drug of Interest ^1,^ ^5^
Levetiracetam | 12 | 12 | 12 | 36
Valproic Acid | 6 | 8 | 8 | 22
Topiramate | 8 | 8 | 10 | 26
Oxcarbazepine | 7 | 8 | 8 | 23

Note:

1 One participant receiving Oxcarbazepine was excluded from all analyses due to concerns regarding the integrity of the data reported for the participant.

2 Safety population includes enrolled and dosed participants.

3 PK population includes all participants with at least 1 available PK sample. Available samples are collected PK samples that are anticipated to be analyzed by a central laboratory.

4 Completed study is defined as having ≥ 3 PK samples of any study drug.

5 Participants may contr bute to more than one drug of interest.

6 One participant in the 12 – <18 years of age group was originally enrolled under oxcarbazepine in ▬ and then re-enrolled under levetiracetam in ▬. Thus, there were 41 enrollments among 40 distinct enrolled participants in this age group.

Table 14.1.2 Participant Enrollment by Site and Age Group All Enrolled Participants

| Age Group
Site | 2 – <6 Years (N = 36) | 6 – <12 Years (N = 41) | 12 – <18 Years ^1^ (N = 40) | Total (N = 117)
▬ | 3 (8.3%) | 1 (2.4%) | 0 | 4 (3.4%)
▬ | 5 (13.9%) | 6 (14.6%) | 4 (10.0%) | 15 (12.8%)
▬ | 0 | 4 (9.8%) | 3 (7.5%) | 7 (6.0%)
▬ | 1 (2.8%) | 0 | 0 | 1 (0.9%)
▬ | 11 (30.6%) | 13 (31.7%) | 13 (32.5%) | 37 (31.6%)
▬ | 3 (8.3%) | 4 (9.8%) | 4 (10.0%) | 11 (9.4%)
▬ | 4 (11.1%) | 5 (12.2%) | 5 (12.5%) | 14 (12.0%)
▬ | 3 (8.3%) | 1 (2.4%) | 1 (2.5%) | 5 (4.3%)
▬ | 1 (2.8%) | 2 (4.9%) | 4 (10.0%) | 7 (6.0%)
▬ | 5 (13.9%) | 5 (12.2%) | 6 (15.0%) | 16 (13.7%)

Note:

1 One participant in the 12 – <18 years of age group was originally enrolled under oxcarbazepine in ▬ and re-enrolled under levetiracetam in ▬. Thus, there were 41 enrollments among 40 distinct enrolled participants in this age group.

Table 14.1.3 Participant Accounting and Final Study Disposition by Age Group All Enrolled Levetiracetam Participants

| Age Group
| 2 – <6 Years (N = 14) | 6 – <12 Years (N = 14) | 12 – <18 Years (N = 14) | Total (N = 42)
Participants Enrolled
Safety population ^1^ | 14 (100.0%) | 14 (100.0%) | 14 (100.0%) | 42 (100.0%)
PK population ^2^ | 14 (100.0%) | 14 (100.0%) | 13 (92.9%) | 41 (97.6%)
Participants with at least 3 PK samples | 12 (85.7%) | 12 (85.7%) | 12 (85.7%) | 36 (85.7%)
Participant Status
Completed study ^3^ | 12 (85.7%) | 12 (85.7%) | 14 (100.0%) | 38 (90.5%)
Early termination | 2 (14.3%) | 2 (14.3%) | 0 | 4 (9.5%)
Reasons for Early Termination
Discharge | 1 (7.1%) | 1 (7.1%) | 0 | 2 (4.8%)
Insufficient sampling | 1 (7.1%) | 1 (7.1%) | 0 | 2 (4.8%)

Note:

1 Safety population includes enrolled and dosed participants.

2 PK population includes all participants with at least 1 available PK sample. Available samples are collected PK samples that are anticipated to be analyzed by a central laboratory.

3 Completed study is defined as having ≥ 3 PK samples of any study drug.

Table 14.1.4 Participant Enrollment by Site and Age Group All Enrolled Levetiracetam Participants

| Age Group
Site | 2 – <6 Years (N = 14) | 6 – <12 Years (N = 14) | 12 – <18 Years (N = 14) | Total (N = 42)
▬ | 2 (14.3%) | 0 | 0 | 2 (4.8%)
▬ | 3 (21.4%) | 1 (7.1%) | 3 (21.4%) | 7 (16.7%)
▬ | 0 | 1 (7.1%) | 2 (14.3%) | 3 (7.1%)
▬ | 4 (28.6%) | 6 (42.9%) | 4 (28.6%) | 14 (33.3%)
▬ | 2 (14.3%) | 1 (7.1%) | 0 | 3 (7.1%)
▬ | 1 (7.1%) | 1 (7.1%) | 2 (14.3%) | 4 (9.5%)
▬ | 2 (14.3%) | 0 | 0 | 2 (4.8%)
▬ | 0 | 2 (14.3%) | 1 (7.1%) | 3 (7.1%)
▬ | 0 | 2 (14.3%) | 2 (14.3%) | 4 (9.5%)

Table 14.1.5 Summary of Participant-specific Protocol Deviations by Site All Enrolled Levetiracetam Participants

| | Inclusion/Exclusion Criteria Deviation | | Informed Consent/Assent Process Executed Incorrectly | | Procedural Error | | Specimen Collection Error | | Total
Site | Total Enrolled Pts | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N | Pts with PD N (%) | Total PDs N
▬ | 2 | 0 | 0 | 0 | 0 | 1 (50.0%) | 1 | 0 | 0 | 1 (50.0%) | 1
▬ | 7 | 0 | 0 | 0 | 0 | 2 (28.6%) | 2 | 0 | 0 | 2 (28.6%) | 2
▬ | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 14 | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (7.1%) | 1 | 2 (14.3%) | 2
▬ | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 4 | 0 | 0 | 0 | 0 | 1 (25.0%) | 1 | 0 | 0 | 1 (25.0%) | 1
▬ | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 3 | 0 | 0 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (33.3%) | 1
▬ | 4 | 0 | 0 | 1 (25.0%) | 1 | 0 | 0 | 2 (50.0%) | 2 | 3 (75.0%) | 3
Total | 42 | 1 (2.4%) | 1 | 2 (4.8%) | 2 | 4 (9.5%) | 4 | 3 (7.1%) | 3 | 10 (23.8%) | 10

Note: Denominators are the number of participants enrolled at each site and overall.

Pts=Participants, PD=Protocol Deviation.

Table 14.1.6 Summary of Participant-specific Protocol Deviations by Reason for Deviation All Enrolled Levetiracetam Participants

| Research Staff Error | | Laboratory Error | | Investigator Decision | | Participant Unable to Comply | | Total
Deviation Classification | Pts with PD N | Total PDs N (%) | Pts with PD N | Total PDs N (%) | Pts with PD N | Total PDs N (%) | Pts with PD N | Total PDs N (%) | Pts with PD N (%) | Total PDs N
Inclusion or Exclusion Criteria Deviation | 1 | 1 (100.0%) | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1 (100.0%)
Informed Consent/Assent Process Executed Incorrectly | 2 | 2 (100.0%) | 0 | 0 | 0 | 0 | 0 | 0 | 2 | 2 (100.0%)
Procedural Error | 1 | 1 (25.0%) | 0 | 0 | 1 | 1 (25.0%) | 2 | 2 (50.0%) | 4 | 4 (100.0%)
Specimen Collection Error | 2 | 2 (66.7%) | 1 | 1 (33.3%) | 0 | 0 | 0 | 0 | 3 | 3 (100.0%)
Total | 6 | 6 (60.0%) | 1 | 1 (10.0%) | 1 | 1 (10.0%) | 2 | 2 (20.0%) | 10 | 10 (100.0%)

Note: Denominator is the number of protocol deviations in each classification and overall.

Pts=Participants, PD=Protocol Deviation.

Table 14.1.7 Demographic and Baseline Characteristics by Age Group Levetiracetam PK Population

| Age Group
| 2 – <6 Years (N = 14) | 6 – <12 Years (N = 14) | 12 – <18 Years (N = 13) | Total (N = 41)
Age, years
N | 14 | 14 | 13 | 41
Mean (SD) | 3.7 (1.4) | 9.1 (1.8) | 15.1 (1.4) | 9.2 (4.9)
Median (Min, Max) | 3.1 (2.1, 5.9) | 8.8 (6.1, 11.8) | 14.9 (13.1, 17.9) | 8.7 (2.1, 17.9)
Gender
Male | 11 (78.6%) | 6 (42.9%) | 5 (38.5%) | 22 (53.7%)
Female | 3 (21.4%) | 8 (57.1%) | 8 (61.5%) | 19 (46.3%)
Ethnicity
Hispanic or Latino | 6 (42.9%) | 2 (14.3%) | 4 (30.8%) | 12 (29.3%)
Not Hispanic or Latino | 8 (57.1%) | 12 (85.7%) | 9 (69.2%) | 29 (70.7%)
Race
White or Caucasian | 6 (42.9%) | 8 (57.1%) | 5 (38.5%) | 19 (46.3%)
Black or African American | 4 (28.6%) | 3 (21.4%) | 6 (46.2%) | 13 (31.7%)
More than one race | 1 (7.1%) | 3 (21.4%) | 1 (7.7%) | 5 (12.2%)
Unknown/not reported | 3 (21.4%) | 0 | 1 (7.7%) | 4 (9.8%)
Weight, kg
N | 14 | 14 | 13 | 41
Mean (SD) | 18.9 (3.8) | 42.8 (12.3) | 87.5 (16.5) | 48.8 (30.8)
Median (Min, Max) | 18.8 (13.8, 24.3) | 43.2 (25.2, 64.0) | 81.4 (70.4, 124.2) | 42.7 (13.8, 124.2)
Weight Percentile
N | 14 | 14 | 13 | 41
Mean (SD) | 83.1 (16.2) | 86.1 (20.2) | 97.1 (2.3) | 88.5 (16.0)
Median (Min, Max) | 88.1 (48.8, 99.8) | 93.0 (34.2, 99.8) | 97.1 (91.7, 99.8) | 95.8 (34.2, 99.8)
Height, cm
N | 14 | 14 | 13 | 41
Mean (SD) | 93.4 (12.8) | 128.9 (15.9) | 164.9 (6.9) | 128.2 (31.8)
Median (Min, Max) | 91.2 (75.0, 111.8) | 131.5 (100.0, 152.0) | 165.1 (156.0, 179.0) | 127.0 (75.0, 179.0)
Height Percentile
N | 14 | 14 | 13 | 41
Mean (SD) | 27.6 (34.6) | 42.4 (42.1) | 54.2 (25.9) | 41.1 (35.8)
Median (Min, Max) | 7.1 (<0.1, 89.8) | 26.7 (<0.1, 98.7) | 45.2 (17.5, 92.5) | 37.2 (<0.1, 98.7)
BMI Percentile
N | 14 | 14 | 13 | 41
Mean (SD) | 99.0 (1.5) | 97.9 (1.6) | 97.4 (1.5) | 98.1 (1.7)
Median (Min, Max) | 99.8 (95.5, >99.9) | 98.2 (95.2, 99.5) | 97.4 (95.3, 99.6) | 98.5 (95.2, >99.9)
Waist Circumference, cm
N | 13 | 14 | 13 | 40
Mean (SD) | 58.2 (8.1) | 80.8 (12.2) | 100.0 (22.6) | 79.7 (22.8)
Median (Min, Max) | 61.0 (33.0, 64.8) | 76.5 (65.5, 111.8) | 104.0 (40.0, 137.2) | 75.5 (33.0, 137.2)
Hip Circumference, cm
N | 13 | 14 | 13 | 40
Mean (SD) | 59.0 (7.8) | 84.8 (11.6) | 105.9 (21.9) | 83.3 (24.1)
Median (Min, Max) | 59.9 (38.1, 68.0) | 83.8 (60.5, 104.1) | 111.0 (47.0, 134.6) | 82.4 (38.1, 134.6)
Waist/Hip Ratio
N | 13 | 14 | 13 | 40
Mean (SD) | 1.0 (0.1) | 1.0 (0.1) | 0.9 (0.1) | 1.0 (0.1)
Median (Min, Max) | 1.0 (0.9, 1.2) | 0.9 (0.9, 1.1) | 0.9 (0.8, 1.2) | 0.9 (0.8, 1.2)

Note: Weight, height, and BMI persentiles were calculated using the parameters obtained from CDC database [https://www.cdc.gov/growthcharts/percentile data files.htm].

Table 14.1.8 Summary of Medical History by System Organ Class, Preferred Term, and Age Group Levetiracetam PK Population

| Age Group | | | | | | Total (N = 41)
| 2 – <6 Years (N = 14) | | 6 – <12 Years (N = 14) | | 12 – <18 Years (N = 13) | | Total (N = 41)
System Organ Class; Preferred Term | Pts with Medical Condition N (%) | Total Medical Conditions N | Pts with Medical Condition N (%) | Total Medical Conditions N | Pts with Medical Condition N (%) | Total Medical Conditions N | Pts with Medical Condition N (%) | Total Medical Conditions N
Nervous system disorders | 13 (92.9%) | 20 | 13 (92.9%) | 35 | 9 (69.2%) | 18 | 35 (85.4%) | 73
Seizure | 5 (35.7%) | 5 | 5 (35.7%) | 5 | 5 (38.5%) | 5 | 15 (36.6%) | 15
Epilepsy | 1 (7.1%) | 1 | 5 (35.7%) | 5 | 2 (15.4%) | 2 | 8 (19.5%) | 8
Hydrocephalus | 3 (21.4%) | 3 | 1 (7.1%) | 2 | 0 | 0 | 4 (9.8%) | 5
Focal dyscognitive seizures | 0 | 0 | 2 (14.3%) | 2 | 1 (7.7%) | 1 | 3 (7.3%) | 3
Hypoxic-ischaemic encephalopathy | 1 (7.1%) | 1 | 2 (14.3%) | 2 | 0 | 0 | 3 (7.3%) | 3
Muscle spasticity | 0 | 0 | 3 (21.4%) | 3 | 0 | 0 | 3 (7.3%) | 3
Partial seizures | 2 (14.3%) | 2 | 1 (7.1%) | 1 | 0 | 0 | 3 (7.3%) | 3
Generalised tonic-clonic seizure | 1 (7.1%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 2 (4.9%) | 2
Headache | 0 | 0 | 1 (7.1%) | 1 | 1 (7.7%) | 1 | 2 (4.9%) | 2
Hemiparesis | 0 | 0 | 0 | 0 | 2 (15.4%) | 2 | 2 (4.9%) | 2
Infantile spasms | 1 (7.1%) | 1 | 1 (7.1%) | 1 | 0 | 0 | 2 (4.9%) | 2
Nervous system disorder | 1 (7.1%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 2 (4.9%) | 2
Tonic convulsion | 1 (7.1%) | 1 | 1 (7.1%) | 1 | 0 | 0 | 2 (4.9%) | 2
Altered state of consciousness | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Cognitive disorder | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Dementia | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Dizziness | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Encephalopathy | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Febrile convulsion | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Hemiplegia | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Idiopathic intracranial hypertension | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Intracranial mass | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Intracranial pressure increased | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Ischaemic stroke | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Language disorder | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Migraine without aura | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Neuropathy peripheral | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Posterior reversible encephalopathy syndrome | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Postictal state | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Rasmussen encephalitis | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Seizure like phenomena | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Somnolence | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Status epilepticus | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Subdural hygroma | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Congenital, familial and genetic disorders | 6 (42.9%) | 13 | 5 (35.7%) | 6 | 3 (23.1%) | 4 | 14 (34.1%) | 23
Cerebral palsy | 1 (7.1%) | 1 | 1 (7.1%) | 1 | 0 | 0 | 2 (4.9%) | 2
Anterior chamber cleavage syndrome | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Arteriovenous malformation | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Bicuspid aortic valve | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Cataract congenital | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Congenital cystic kidney disease | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Congenital cytomegalovirus infection | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Congenital hepatic fbrosis | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Cortical dysplasia | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Cryptorchism | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
DiGeorge’s syndrome | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Diencephalic syndrome of infancy | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Dilatation intrahepatic duct congenital | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Macrocephaly | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Mucopolysaccharidosis I | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Mucopolysaccharidosis II | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Neurofibromatosis | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Pulmonary hypoplasia | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Rett syndrome | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Schizencephaly | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Thyroglossal cyst | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Tuberous sclerosis complex | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Respiratory, thoracic and mediastinal disorders | 6 (42.9%) | 8 | 5 (35.7%) | 6 | 3 (23.1%) | 3 | 14 (34.1%) | 17
Acute respiratory failure | 0 | 0 | 1 (7.1%) | 1 | 1 (7.7%) | 1 | 2 (4.9%) | 2
Chronic respiratory failure | 1 (7.1%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 2 (4.9%) | 2
Hypoxia | 1 (7.1%) | 1 | 1 (7.1%) | 1 | 0 | 0 | 2 (4.9%) | 2
Lung disorder | 1 (7.1%) | 1 | 1 (7.1%) | 1 | 0 | 0 | 2 (4.9%) | 2
Adenoidal hypertrophy | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Asthma | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Bronchial hyperreactivity | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Interstitial lung disease | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Pulmonary hypertension | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Respiratory failure | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Restrictive pulmonary disease | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Sleep apnoea syndrome | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Status asthmaticus | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Metabolism and nutrition disorders | 1 (7.1%) | 2 | 7 (50.0%) | 7 | 4 (30.8%) | 5 | 12 (29.3%) | 14
Abnormal weight gain | 0 | 0 | 2 (14.3%) | 2 | 0 | 0 | 2 (4.9%) | 2
Hypocalcaemia | 0 | 0 | 2 (14.3%) | 2 | 0 | 0 | 2 (4.9%) | 2
Obesity | 0 | 0 | 1 (7.1%) | 1 | 1 (7.7%) | 1 | 2 (4.9%) | 2
Type 2 diabetes mellitus | 0 | 0 | 0 | 0 | 2 (15.4%) | 2 | 2 (4.9%) | 2
Hypercalcaemia | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Hyperglycaemia | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Hypoglycaemia | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Hyponatraemia | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Type 1 diabetes mellitus | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Vitamin D deficiency | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Surgical and medical procedures | 6 (42.9%) | 12 | 2 (14.3%) | 3 | 3 (23.1%) | 6 | 11 (26.8%) | 21
Tracheostomy | 3 (21.4%) | 3 | 1 (7.1%) | 1 | 1 (7.7%) | 1 | 5 (12.2%) | 5
Ventriculo-peritoneal shunt | 2 (14.3%) | 2 | 1 (7.1%) | 1 | 0 | 0 | 3 (7.3%) | 3
Craniotomy | 0 | 0 | 0 | 0 | 1 (7.7%) | 2 | 1 (2.4%) | 2
Chemotherapy | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Colectomy | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Colostomy | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Ethmoid sinus surgery | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Gastrostomy | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Heart transplant | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Hepatectomy | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Implantable defibrillator insertion | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Liver transplant | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Renal transplant | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Sinus antrostomy | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Psychiatric disorders | 0 | 0 | 6 (42.9%) | 7 | 3 (23.1%) | 5 | 9 (22.0%) | 12
Attention deficit hyperactivity disorder | 0 | 0 | 2 (14.3%) | 2 | 1 (7.7%) | 1 | 3 (7.3%) | 3
Depression | 0 | 0 | 0 | 0 | 2 (15.4%) | 2 | 2 (4.9%) | 2
Abnormal behaviour | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Adjustment disorder with anxiety | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Affective disorder | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Aggression | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Breathing-related sleep disorder | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Enuresis | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Oppositional defiant disorder | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Gastrointestinal disorders | 2 (14.3%) | 2 | 3 (21.4%) | 3 | 3 (23.1%) | 3 | 8 (19.5%) | 8
Gastrooesophageal reflux disease | 1 (7.1%) | 1 | 1 (7.1%) | 1 | 1 (7.7%) | 1 | 3 (7.3%) | 3
Constipation | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Impaired gastric emptying | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Intestinal steatosis | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Pancreatitis acute | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Short-bowel syndrome | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
General disorders and administration site conditions | 5 (35.7%) | 5 | 1 (7.1%) | 2 | 2 (15.4%) | 3 | 8 (19.5%) | 10
Developmental delay | 3 (21.4%) | 3 | 1 (7.1%) | 1 | 1 (7.7%) | 1 | 5 (12.2%) | 5
Hypothermia | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Mucosal inflammation | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Oedema peripheral | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Performance status decreased | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Systemic inflammatory response syndrome | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Vascular disorders | 3 (21.4%) | 3 | 2 (14.3%) | 2 | 3 (23.1%) | 3 | 8 (19.5%) | 8
Hypertension | 2 (14.3%) | 2 | 0 | 0 | 1 (7.7%) | 1 | 3 (7.3%) | 3
Aortic aneurysm | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Essential hypertension | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Secondary hypertension | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Shock | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Vasculitis | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Cardiac disorders | 2 (14.3%) | 2 | 3 (21.4%) | 4 | 2 (15.4%) | 2 | 7 (17.1%) | 8
Cardiac arrest | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Cardiac failure | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Cardio-respiratory arrest | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Cyanosis | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Intracardiac thrombus | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Long QT syndrome | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Ventricular tachycardia | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Wolff-Parkinson-White syndrome | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Infections and infestations | 1 (7.1%) | 2 | 3 (21.4%) | 5 | 2 (15.4%) | 3 | 6 (14.6%) | 10
Brain empyema | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Clostridium difficile colitis | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Encephalitis | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Enterovirus infection | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Gastroenteritis | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Nasopharyngitis | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Pneumonia | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Sinusitis | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Tracheitis | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Urinary tract infection bacterial | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Neoplasms benign, malignant and unspecified (incl cysts and polyps) | 2 (14.3%) | 4 | 2 (14.3%) | 2 | 2 (15.4%) | 2 | 6 (14.6%) | 8
Acute lymphocytic leukaemia | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Acute lymphocytic leukaemia (in remission) | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Astrocytoma | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Central nervous system neoplasm | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Pineal germinoma | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Pineal neoplasm | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Rhabdomyoma | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
T-cell lymphoma | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Investigations | 1 (7.1%) | 1 | 1 (7.1%) | 1 | 3 (23.1%) | 3 | 5 (12.2%) | 5
Blood testosterone increased | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Body mass index increased | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
C-reactive protein increased | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Cardiac murmur | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Electroencephalogram abnormal | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Blood and lymphatic system disorders | 3 (21.4%) | 3 | 1 (7.1%) | 1 | 0 | 0 | 4 (9.8%) | 4
Anaemia | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Coagulopathy | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Leukocytosis | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Pancytopenia | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Endocrine disorders | 1 (7.1%) | 2 | 3 (21.4%) | 5 | 0 | 0 | 4 (9.8%) | 7
Hypothyroidism | 1 (7.1%) | 1 | 2 (14.3%) | 2 | 0 | 0 | 3 (7.3%) | 3
Adrenal insufficiency | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Hyperparathyroidism secondary | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Hypoparathyroidism | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Precocious puberty | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Eye disorders | 2 (14.3%) | 2 | 1 (7.1%) | 1 | 0 | 0 | 3 (7.3%) | 3
Blindness cortical | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Mydriasis | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Strabismus | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Musculoskeletal and connective tissue disorders | 0 | 0 | 2 (14.3%) | 6 | 1 (7.7%) | 1 | 3 (7.3%) | 7
Scoliosis | 0 | 0 | 2 (14.3%) | 2 | 1 (7.7%) | 1 | 3 (7.3%) | 3
Tendinous contracture | 0 | 0 | 1 (7.1%) | 2 | 0 | 0 | 1 (2.4%) | 2
Foot deformity | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Osteoporosis | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Ear and labyrinth disorders | 1 (7.1%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 2 (4.9%) | 2
Deafness | 1 (7.1%) | 1 | 0 | 0 | 1 (7.7%) | 1 | 2 (4.9%) | 2
Injury, poisoning and procedural complications | 0 | 0 | 0 | 0 | 2 (15.4%) | 7 | 2 (4.9%) | 7
Facial bones fracture | 0 | 0 | 0 | 0 | 1 (7.7%) | 2 | 1 (2.4%) | 2
Extradural haematoma | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Fall | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Injury | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Pulmonary contusion | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Scapula fracture | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Renal and urinary disorders | 2 (14.3%) | 2 | 0 | 0 | 0 | 0 | 2 (4.9%) | 2
Chronic kidney disease | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Renal hypertension | 1 (7.1%) | 1 | 0 | 0 | 0 | 0 | 1 (2.4%) | 1
Social circumstances | 0 | 0 | 1 (7.1%) | 1 | 1 (7.7%) | 1 | 2 (4.9%) | 2
Familial risk factor | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Feeding tube user | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Pregnancy, puerperium and perinatal conditions | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Premature baby | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Reproductive system and breast disorders | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Vulvovaginal pain | 0 | 0 | 0 | 0 | 1 (7.7%) | 1 | 1 (2.4%) | 1
Skin and subcutaneous tissue disorders | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1
Intertrigo | 0 | 0 | 1 (7.1%) | 1 | 0 | 0 | 1 (2.4%) | 1

Note: Pts=Participants.

Table 14.3.6 Clinical Laboratory Evaluations by Age Group Levetiracetam PK Population

| Age Group
| 2 – <6 Years (N = 14) | 6 – <12 Years (N = 14) | 12 – <18 Years (N = 13) | Total (N = 41)
Albumin, g/dL
N | 12 | 14 | 13 | 39
Mean (SD) | 3.8 (0.7) | 3.7 (0.9) | 3.5 (0.6) | 3.7 (0.7)
Median (Min, Max) | 4.0 (2.5, 4.7) | 3.8 (2.4, 5.3) | 3.5 (2.8, 4.4) | 3.7 (2.4, 5.3)
ALT, U/L
N | 12 | 14 | 13 | 39
Mean (SD) | 60.3 (92.7) | 29.1 (17.8) | 46.2 (52.0) | 44.4 (60.1)
Median (Min, Max) | 28.0 (8.0, 344.0) | 20.0 (6.0, 70.0) | 23.0 (13.0, 204.0) | 23.0 (6.0, 344.0)
AST, U/L
N | 12 | 14 | 13 | 39
Mean (SD) | 43.8 (24.5) | 33.1 (19.6) | 33.1 (25.1) | 36.4 (23.0)
Median (Min, Max) | 38.0 (22.0, 119.0) | 25.0 (14.0, 76.0) | 30.0 (10.0, 99.0) | 31.0 (10.0, 119.0)
Blood Urea Nitrogen, mg/dL
N | 14 | 14 | 12 | 40
Mean (SD) | 15.8 (14.1) | 8.2 (4.2) | 9.7 (3.8) | 11.3 (9.3)
Median (Min, Max) | 11.5 (2.0, 57.0) | 8.5 (1.0, 16.0) | 9.0 (5.0, 18.0) | 10.0 (1.0, 57.0)
Creatinine, mg/dL
N | 14 | 14 | 12 | 40
Mean (SD) | 0.6 (1.0) | 0.5 (0.2) | 0.5 (0.2) | 0.5 (0.6)
Median (Min, Max) | 0.3 (0.2, 3.9) | 0.5 (0.2, 0.8) | 0.6 (0.2, 0.8) | 0.4 (0.2, 3.9)
Protein (Total), g/dL
N | 10 | 12 | 11 | 33
Mean (SD) | 6.7 (1.0) | 7.1 (1.2) | 6.5 (0.7) | 6.8 (1.0)
Median (Min, Max) | 7.0 (4.5, 8.1) | 7.3 (4.5, 9.5) | 6.5 (5.4, 7.8) | 6.9 (4.5, 9.5)

Table 14.3.7 Summary of Concomitant Medications of Interest by Age Group Levetiracetam PK Population

| Age Group
| 2 – <6 Years (N = 14) | 6 – <12 Years (N = 14) | 12 – <18 Years (N = 13) | Total (N = 41)
Any Medication | 2 (14.3%) | 5 (35.7%) | 4 (30.8%) | 11 (26.8%)
Ketorolac | 0 | 1 (7.1%) | 0 | 1 (2.4%)
Phenobarbital | 1 (7.1%) | 0 | 1 (7.7%) | 2 (4.9%)
Phenytoin | 0 | 0 | 1 (7.7%) | 1 (2.4%)
Topiramate | 0 | 2 (14.3%) | 0 | 2 (4.9%)
Valproic acid | 0 | 2 (14.3%) | 1 (7.7%) | 3 (7.3%)
Oxcarbazepine | 2 (14.3%) | 0 | 2 (15.4%) | 4 (9.8%)

Note: For participants receiving multiple drugs of interest (DOIs), those DOIs were reported solely on the treatment administration form. Given all DOIs other than Levetiracetam are considered concomitant medications of interest for Levetiracetam, additional DOI data provided on the treatment administration form was also included in the table.

Table 14.3.8 Summary of Physical Examination Findings by Body System and Age Group Levetiracetam PK Population

| Age Group
Body System | 2 – <6 Years (N = 14) | 6 – <12 Years (N = 14) | 12 – <18 Years (N = 13) | Total (N = 41)
General Appearance
Normal | 12 (85.7%) | 14 (100.0%) | 11 (84.6%) | 37 (90.2%)
Abnormal, not clinically significant | 2 (14.3%) | 0 | 0 | 2 (4.9%)
Abnormal, clinically significant | 0 | 0 | 2 (15.4%) | 2 (4.9%)
Not done | 0 | 0 | 0 | 0
General Behavior
Normal | 10 (71.4%) | 14 (100.0%) | 10 (76.9%) | 34 (82.9%)
Abnormal, not clinically significant | 1 (7.1%) | 0 | 1 (7.7%) | 2 (4.9%)
Abnormal, clinically significant | 3 (21.4%) | 0 | 2 (15.4%) | 5 (12.2%)
Not done | 0 | 0 | 0 | 0
Skin
Normal | 11 (78.6%) | 13 (92.9%) | 10 (76.9%) | 34 (82.9%)
Abnormal, not clinically significant | 3 (21.4%) | 1 (7.1%) | 2 (15.4%) | 6 (14.6%)
Abnormal, clinically significant | 0 | 0 | 1 (7.7%) | 1 (2.4%)
Not done | 0 | 0 | 0 | 0
Ears, Nose, Mouth and Throat
Normal | 12 (85.7%) | 12 (85.7%) | 13 (100.0%) | 37 (90.2%)
Abnormal, not clinically significant | 1 (7.1%) | 2 (14.3%) | 0 | 3 (7.3%)
Abnormal, clinically significant | 1 (7.1%) | 0 | 0 | 1 (2.4%)
Not done | 0 | 0 | 0 | 0
Cardiovascular
Normal | 13 (92.9%) | 13 (92.9%) | 13 (100.0%) | 39 (95.1%)
Abnormal, not clinically significant | 0 | 1 (7.1%) | 0 | 1 (2.4%)
Abnormal, clinically significant | 1 (7.1%) | 0 | 0 | 1 (2.4%)
Not done | 0 | 0 | 0 | 0
Respiratory
Normal | 8 (57.1%) | 11 (78.6%) | 12 (92.3%) | 31 (75.6%)
Abnormal, not clinically significant | 4 (28.6%) | 3 (21.4%) | 1 (7.7%) | 8 (19.5%)
Abnormal, clinically significant | 2 (14.3%) | 0 | 0 | 2 (4.9%)
Not done | 0 | 0 | 0 | 0
Gastrointestinal (Abdomen)
Normal | 9 (64.3%) | 11 (78.6%) | 12 (92.3%) | 32 (78.0%)
Abnormal, not clinically significant | 3 (21.4%) | 2 (14.3%) | 0 | 5 (12.2%)
Abnormal, clinically significant | 2 (14.3%) | 0 | 0 | 2 (4.9%)
Not done | 0 | 1 (7.1%) | 1 (7.7%) | 2 (4.9%)
Neurologic
Normal | 8 (57.1%) | 14 (100.0%) | 7 (53.8%) | 29 (70.7%)
Abnormal, not clinically significant | 3 (21.4%) | 0 | 2 (15.4%) | 5 (12.2%)
Abnormal, clinically significant | 3 (21.4%) | 0 | 4 (30.8%) | 7 (17.1%)
Not done | 0 | 0 | 0 | 0
Musculoskeletal
Normal | 9 (64.3%) | 14 (100.0%) | 11 (84.6%) | 34 (82.9%)
Abnormal, not clinically significant | 3 (21.4%) | 0 | 2 (15.4%) | 5 (12.2%)
Abnormal, clinically significant | 2 (14.3%) | 0 | 0 | 2 (4.9%)
Not done | 0 | 0 | 0 | 0
Lymphatic (e.g., Anasarca, Peripheral Edema)
Normal | 10 (71.4%) | 13 (92.9%) | 12 (92.3%) | 35 (85.4%)
Abnormal, not clinically significant | 2 (14.3%) | 0 | 0 | 2 (4.9%)
Abnormal, clinically significant | 0 | 0 | 0 | 0
Not done | 2 (14.3%) | 1 (7.1%) | 1 (7.7%) | 4 (9.8%)
Other
Normal | 0 | 0 | 1 (7.7%) | 1 (2.4%)
Abnormal, not clinically significant | 0 | 0 | 0 | 0
Abnormal, clinically significant | 0 | 0 | 0 | 0
Not done | 0 | 0 | 0 | 0

Table 14.3.9 Summary of Study Doses by Age Group Levetiracetam PK Population

| Age Group
| 2 – <6 Years (N = 14) | 6 – <12 Years (N = 14) | 12 – <18 Years (N = 13) | Total (N = 41)
Days of Study Dosing ^1^
Average dosing days | 2.0 | 1.1 | 5.2 | 2.7
1 | 10 (71.4%) | 13 (92.9%) | 7 (53.8%) | 30 (73.2%)
2 | 1 (7.1%) | 1 (7.1%) | 3 (23.1%) | 5 (12.2%)
3 | 2 (14.3%) | 0 | 2 (15.4%) | 4 (9.8%)
10 | 1 (7.1%) | 0 | 0 | 1 (2.4%)
48 | 0 | 0 | 1 (7.7%) | 1 (2.4%)
Number of Study Doses per Participant ^2^
Average number of doses | 3.7 (4.6) | 1.9 (0.8) | 3.3 (1.8) | 3.0 (3.0)
1 | 2 (14.3%) | 5 (35.7%) | 1 (7.7%) | 8 (19.5%)
2 | 7 (50.0%) | 6 (42.9%) | 4 (30.8%) | 17 (41.5%)
3 | 2 (14.3%) | 3 (21.4%) | 4 (30.8%) | 9 (22.0%)
4 | 0 | 0 | 2 (15.4%) | 2 (4.9%)
5 | 1 (7.1%) | 0 | 0 | 1 (2.4%)
6 | 1 (7.1%) | 0 | 0 | 1 (2.4%)
7 | 0 | 0 | 2 (15.4%) | 2 (4.9%)
19 | 1 (7.1%) | 0 | 0 | 1 (2.4%)
Mean Administered Study Dose ^3^, mg/kg
N | 14 | 14 | 13 | 41
Mean (SD) | 22.6 (14.9) | 19.3 (7.5) | 13.1 (7.2) | 18.5 (11.0)
Median (Min, Max) | 19.0 (9.1, 66.7) | 18.9 (8.2, 30.9) | 9.2 (4.8, 24.6) | 17.2 (4.8, 66.7)

Note:

1 Days of study dosing is defined as days from the dose administered closest in time to the first PK sample until the final PK sample.

2 Study dose is defined as the dose administered closest in time to the first PK sample until the final PK sample.

3 Mean administered study dose was calculated by (sum of dose (mg) × number of doses / total number of doses) / participant weight (kg).

Table 14.3.10 Summary of PK Samples by Age Group Levetiracetam PK Population

| Age Group
| 2 – <6 Years (N = 14) | 6 – <12 Years (N = 14) | 12 – <18 Years (N = 13) | Total (N = 41)
Number of PK Samples | 51 | 48 | 53 | 152
Number of PK Samples per Participant
N | 14 | 14 | 13 | 41
Mean (SD) | 3.6 (1.3) | 3.4 (1.3) | 4.1 (1.0) | 3.7 (1.2)
Median (Min, Max) | 3.0 (2.0, 6.0) | 3.5 (1.0, 5.0) | 4.0 (2.0, 5.0) | 4.0 (1.0, 6.0)

Note: N is number of participants unless specified.

Figure 14.4.1 Box Plot of Clinical Laboratory Evaluations by Age Group Levetiracetam PK Population

A. Albumin (g/dL)

Figure 14.4.1 Box Plot of Clinical Laboratory Evaluations by Age Group Levetiracetam PK Population

B. ALT (U/L)

Figure 14.4.1 Box Plot of Clinical Laboratory Evaluations by Age Group Levetiracetam PK Population

C. AST (U/L)

Figure 14.4.1 Box Plot of Clinical Laboratory Evaluations by Age Group Levetiracetam PK Population

D. Blood Urea Nitrogen (mg/dL)

Figure 14.4.1 Box Plot of Clinical Laboratory Evaluations by Age Group Levetiracetam PK Population

E. Creatinine (mg/dL)

Figure 14.4.1 Box Plot of Clinical Laboratory Evaluations by Age Group Levetiracetam PK Population

F. Protein (Total) (g/dL)

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 2

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 5

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 13

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 7

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 3

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 14

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: Valproic acid

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 5

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 15

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 5

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 15

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: Oxcarbazepine

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 17

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 10

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 2

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: Phenobarbital, Oxcarbazepine

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 2

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 11

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None.

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 5

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 2

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 15

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None.

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 8

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: Topiramate

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 13

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 8

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None.

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 9

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: None

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 11

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: Topiramate

Figure 14.4.2 Participant Profile Plots

Participant: ▬

Age at Enrollment (year): 16

Final PK sample marks the end of study.

For Adverse Events: SAE=Serious Adverse Event.

Concomitant medications of interest the participant received: Oxcarbazepine.