# 5 ETHICS

## 5.1 Institutional Review Boards (IRBs)

Institutional Review Board (IRB) approval of the protocol, informed consent documents, and other participant facing information and recruitment materials was obtained prior to the conduct of any study activities at a study site. Any amendments to the protocol received IRB approval prior to implementation of any changes made to the study design. Detailed IRB information is provided in Section 16.1.3.

## 5.2 Ethical Conduct of the Study

The study was conducted in accordance with the ethical principles originating from the Declaration of Helsinki and International Council for Harmonisation (ICH) guidelines for Good Clinical Practice (GCP) and in compliance with US federal, state, and local regulatory requirements. Applicable sections of the Code of Federal Regulations (CFR) included, but were not limited to, 21 CFR 312 (Investigational New Drug Application), 21 CFR 50 (Protection of Human Subjects), 45 CFR part 46 (Protection of Human Subjects), 45 CFR 164 (Security and Privacy), and 21 CRF 56 (Institutional Review Boards).

## 5.3 Participant Information and Consent

All participants in this study were minors under 18 years of age at enrollment. The investigator or designated representative explained the nature of the study to the participant and/or the participant’s parents or legal guardian, as applicable, to the extent compatible with the participant’s understanding, and answered all questions regarding this study. Prior to any study-related procedures being performed on the participant, informed consent (parental permission) was signed and dated by the participant’s parent or legal guardian, and by the person who obtained the informed consent, as applicable. The participant gave assent when appropriate. A copy of the signed informed consent form (ICF) was given to the participant’s parent or legal guardian, and the original was placed in the study record. All consent forms used in this study were IRB-approved.

The informed consent process was documented in the participant’s source records to confirm that informed parental/guardian permission was obtained prior to any study-related procedures and that the participant’s parent or legal guardian, received a signed copy. In addition, the Health Insurance Portability and Accountability Act (HIPAA) statement was reviewed, signed, and dated by the participant’s parent or legal guardian as a part of the ICF or as a separate form. A sample ICF is provided in Section 16.1.3.