# Descriptive Supplementary Documents

- Levetiracetam Case Report Forms for Data Collection
- Levetiracetam Data Dictionary
- Levetiracetam Pharmacokinetic Study Report
- Levetiracetam Study Protocol
- Levetiracetam Rules for Data Redaction/De-Identification
- Levetiracetam Statistical Analysis Plan
- Levetiracetam Proposed Label Change for Solution
- Levetiracetam Proposed Label Change for Tablet