# 16 APPENDICES

16.1 Study Information
  16.1.1 Protocol and Amendments
    16.1.1.1 AED01 Protocol and Amendments
    16.1.1.2 POP01 Protocol and Amendments
  16.1.2 Sample Case Report Form (CRF)
    16.1.2.1 AED01 CRF
    16.1.2.2 POP01 CRF
  16.1.3 IRBs, REBs, and Informed Consent Templates
    16.1.3.1 AED01 IRBs, REBs, and Informed Consent Templates
    16.1.3.2 POP01 IRBs, REBs, and Informed Consent Templates
  16.1.4 Investigator Information
    16.1.4.1 AED01 Investigator Information
    16.1.4.2 POP01 Investigator Information
  16.1.5 CSR Signatures of Principal Investigators
  16.1.6 Investigational Product Batch Listing (AED01)
  16.1.7 Randomization Scheme and Codes (AED01)
  16.1.8 Audit Certificates (AED01)
  16.1.9 Statistical Analysis Plan (AED01)
  16.1.10 Inter-laboratory Standardization Methods (AED01)
  16.1.11 Publications Based on the Study (AED01)
  16.1.12 Important Publications Referenced in the Report (AED01)
16.2 Patient Data Listings (AED01)
16.3 Case Report Forms (AED01)
  CRFs for deaths, other serious adverse events, and any withdrawals as the result of an AE
16.4 PK Analyses and Supporting Information (AED01, POP01)
  16.4.1 PK Report
  16.4.2 PK Dataset and Define.pdf
  16.4.3 NONMEM Code, Control Streams, Output
  16.4.4 Method Validation Report
  16.4.5 Bioanalytical Report
16.5 Raw Datasets and Define.pdf (AED01 – levetiracetam)

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/417560