# 4 GLOSSARY OF ABBREVIATIONS AND TERMS

Abbreviation: Definition
AE: Adverse Event
ACV: Acyclovir
ALT: Alanine Transaminase
ANC: Absolute Neutrophil Count
AST: Aspartate Transaminase
BPCA: Best Pharmaceuticals for Children Act
BUN: Blood Urea Nitrogen
CFR: Code of Federal Regulations
▬: ▬▬▬▬▬
CL: Clearance
CNS: Central Nervous System
CL: Confidence Level
CSF: Cerebrospinal fluid
DCC: Data Coordinating Center
DCRI: Duke Clinical Research Institute
DMC: Data Monitoring Committee
DNA: Deoxyribonucleic Acid
DUMC: Duke University Medical Center
eCRF: Electronic Case Report Form
FDA: Food and Drug Administration
GA: Gestational Age
GCP: Good Clinical Practice
G-CSF: Granulocyte Colony Stimulating Factor
GGT: Gamma-glutamyl transpeptidase
HD: High Dose
HIPAA: Health Insurance Portability and Accountability Act
HSV: Herpes Simplex Virus
ICH: International Conference on Harmonisation
ID: Intermediate Dose
IND: Investigational New Drug application
IRB: Institutional Review Board
IVH: Intraventricular Hemorrhage
kg: Kilogram
MedDRA: Medical Dictionary for Regulatory Activities
mg: Milligram
N: Number (typically refers to participants)
NICHD: National Institute of Child Health and Human Development
NDI: Neurodevelopment impairment
NEC: Necrotizing Enterocolitis
NICU: Neonatal Intensive Care Unit
NIH: National Institutes of Health
OR: Odds Ratio
PCR: Polymerase Chain Reaction
PD: Pharmacodynamics
PI: Principal Investigator
PK: Pharmacokinetics
PMA: Post Menstrual Age
PNA: Post Natal Age
POPS: Pharmacokinetics of Understudied Drugs Administered to Children per Standard of Care
PPRU: Pediatric Pharmacology Research Unit
PTN: Pediatric Trials Network
ROP: Retinopathy of Prematurity
SAE: Serious Adverse Event
SD: Standard Dose
SEM: Skin Eye and Mouth
▬: ▬▬▬▬▬
▬: ▬▬▬▬▬
V: Volume of Distribution
WBC: White Blood Count