# 2 SYNOPSIS

NAME OF SPONSOR: The Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD)

NAME OF STUDY DRUG: Acyclovir

TITLE OF STUDY: Safety and Efficacy of High-Dose Acyclovir in Infants with HSV or Suspected HSV

PRINCIPAL INVESTIGATOR: P. Brian Smith, MD, MPH, MHS, Duke University Medical Center

PUBLICATIONS: None

STUDY PERIOD: | PHASE OF DEVELOPMENT:
(Date of First Participant Visit): Not applicable; (Date of Last Participant Visit): Not applicable | Data Analysis

PRIMARY OBJECTIVES:

1. To characterize the safety of high-dose acyclovir
2. To characterize the therapeutic efficacy of high-dose acyclovir

METHODOLOGY: This retrospective study included the analysis of data from the Pediatrix Medical Group database and a review of medical charts from infants who had been admitted to intensive care nurseries at 4 different sites and received acyclovir as standard of care.

NUMBER OF PARTICIPANTS (PLANNED AND ANALYZED):

Planned: Approximately 860 infants (database and medical chart review)

Analyzed:

- Pediatrix Medical Group Database: 368
- Medical Chart Review: 49

INCLUSION AND EXCLUSION CRITERIA:

[underlined: Inclusion criteria for the Pediatrix Medical Group (PMG) database review included]:

1. Infants discharged from an intensive care nursery managed by the Pediatrix Medical Group from 2002 to 2012 (Discharged status include discharged home, discharged to another hospital, or death).
2. Neonatal herpes simplex virus (HSV) infection defined as ≥1 of the following features:
  - Positive HSV deoxyribonucleic acid (DNA) polymerase chain reaction (PCR) in ≥1 site:
    - Blood
    - Cerebrospinal fluid (CSF)
    - Skin, mouth, naso/oropharynx, conjunctivae, urine, stool or rectum obtained ≥24 hours after birth
    - From swabs or scrapings of skin or mucous membrane lesions
  - Positive HSV culture in ≥1 sites:
    - Blood
    - CSF
    - Skin, mouth, naso/oropharynx, conjunctivae, urine, stool or rectum obtained ≥24 hours after birth
  - Positive HSV direct immunofluorescence assay from swabs or scrapings of skin or mucous membrane lesions
  - Clinical diagnosis of HSV
3. ≥21 days of acyclovir therapy unless the infant died prior to Day 21 of therapy.
4. <120 days of age at the first dose of acyclovir.

[underlined: Inclusion criteria for the Medical Chart Review included:]

1. HSV infection defined as ≥1 of the following features:
  - Positive HSV DNA PCR in ≥1 sites:
    - Blood
    - CSF
    - Skin, mouth, naso/oropharynx, conjunctivae, urine, stool or rectum obtained ≥24 hours after birth
    - From swabs or scrapings of skin or mucous membrane lesions
  - Positive HSV culture in ≥1 sites:
    - Blood
    - CSF
    - Skin, mouth, naso/oropharynx, conjunctivae, urine, stool or rectum obtained ≥24 hours after birth
  - Clinical Diagnosis of HSV
2. ≥21 days of acyclovir therapy unless the infant died prior to day 21 of therapy.
3. <120 days of age at first dose.

TEST PRODUCT, DOSE AND MODE OF ADMINISTRATION, BATCH NUMBER:

Duration of Treatment:

Not applicable. This was an observational, retrospective study.

Reference Therapy, Dose and Mode of Administration, Batch Number:

Not applicable.

CRITERIA FOR EVALUATION:

This was an observational, retrospective study using data from existing medical records, and an established data repository (Pediatrix Medical Group [PMG]). For the medical chart review, infants with confirmed or suspected HSV from Duke University Medical Center (DUMC), Children’s Hospital of Orange County (CHOC), University of North Carolina (UNC) and Cincinnati Children’s Hospital (CIN) were identified to evaluate the safety of high-dose (HD) acyclovir (60 mg/kg/day). Data were also obtained from the PMG database for those participants meeting the defined inclusion criteria.

STATISTICAL METHODS:

For the safety analyses, the frequency of diagnostic and safety adverse events were summarized using standard summary statistics. For the analysis of medical chart review data, intravenous acyclovir dosing was summarized by adverse event occurrence.

RESULTS:

Efficacy: Efficacy was not assessed in this analysis.

Safety: Among the infants identified in the medical chart review, mortality was high (18%) and was highest among the most immature infants, 23-29 weeks GA (33%). Rash was the most common diagnostic AE reported (37%). Elevated liver enzymes were the most commonly reported laboratory AEs. Dose amount was not related to occurrence of diagnostic AEs. Many of the AEs may be related to the underlying illness (e.g., rash, hypotension, seizure, elevated liver enzymes).

CONCLUSIONS:

The standard of care for IV acyclovir dosing in infants with HSV is 20 mg/kg every 8 hours. From our previous PK study, we found that exposure was related to maturity and resulted in our recommendation for dosing based on PMA [11]. Here we have provided safety data from 2 sources (PMG database and a medical chart review). From the chart review, most IV dosing was well above the FDA labeled dosing and many infants were exposed to doses in excess of 20 mg/kg every 8 hours. Given the prior publication of the efficacy of 20 mg/kg every 8 hours relative to 10 mg/kg every 8 hours [4,8], the PK data previously submitted [11], and the PMG database and medical chart review safety data, acyclovir should be dosed higher than the dosing currently outlined in the FDA label.