# 13 DISCUSSION AND OVERALL CONCLUSIONS

## 13.1 Overall Conclusions

The standard of care for IV acyclovir dosing in neonates with HSV is 20 mg/kg every 8 hours. From our previous PK study, we found that exposure was related to maturity and resulted in our recommendation for dosing based on PMA [11]. Here we have provided safety data from 2 sources (PMG database and a medical chart review). From the chart review, most IV dosing was well above the FDA labeled dosing and many infants were exposed to doses in excess of 20 mg/kg every 8 hours. Given the prior publication of the efficacy of 20 mg/kg every 8 hours relative to 10 mg/kg every 8 hours [4,8], the PK data previously submitted [11], and the PMG database and medical chart review safety data, acyclovir should be dosed higher than the dosing currently outlined in the FDA label.