# 12 SAFETY EVALUATION

Safety was assessed retrospectively using data from the Pediatrix Medical Group database and medical chart review.

## 12.1 Pediatrix Administrative Database Safety Analysis

Please see Appendix 16.4.1 for the complete data report.

## 12.2 Medical Chart Review

### 12.2.1 Adverse Events

#### 12.2.1.1 Death

Table 12-1 summarizes death events by GA and PNA group while participants were on IV acyclovir. Nine (18%) participants died on the days exposed to IV acyclovir: the GA 23-29 weeks group reported the highest death rate of 2 (33%), 2 (20%) died in the GA 30-34 weeks group, 5 died (20%) in the GA 35-42 weeks PNA <14 days group, and no participants died in the GA 35-42 weeks PNA ≥14 days group. ▬ had the highest death rate 6 (46%), 2 (22%) deaths were reported at ▬, 1 (5%) at ▬ and no deaths were reported at ▬. Six (25%) participants who died were female, and 3 (12%) were male. The median cumulative doses for the surviving and deceased participants while on IV acyclovir were 1340 mg/kg and 156 mg/kg, respectively. The median maximum doses for the surviving and deceased participants were 82 mg/kg/day and 60 mg/kg/day. The median daily dose on the days that participants died was 20 mg/kg/day. Three participants died after exposure to IV acyclovir; 2 deaths were reported 1 day after the last study dose.

Table 12-1 Death by GA and PNA group

| GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
Number of Deaths | 2 (33.3%) | 2 (20.0%) | 5 (20.0%) | 0 | 9 (18.4%)

#### 12.2.1.2 Diagnosis AEs

An overall summary of diagnosis AEs by GA and PNA group and site is presented in Tables 14.2.1.1.1, 14.2.1.1.2, 14.2.1.2.1, 14.2.1.2.2, 14.2.1.3.1 to 14.2.1.3.7, 12-2 and 12-3. There were no participants with reported medical NEC, surgical NEC, spontaneous intestinal perforation, hyperbilirubinemia requiring exchange transfusion and neutropenia requiring G-CSF.

Participants in the GA 23-29 and 30-34 week groups had similar incidence of rash events (3/6, 50%, in GA 23-29 weeks and 6/10, 60%, in GA 30-34 weeks). Participants in the GA 23-29 and GA 35-42 weeks PNA <14 days groups had similar incidence of hypotension (2/6, 33%, in GA 23-29 weeks and 8/25, 32%, in GA 35-42 weeks PNA <14 days group). The GA 35-42 weeks PNA ≥14 days group had the highest incidence of seizure (3/8, 38%) and intraventricular hemorrhage (2/8, 25%). All 3 renal failure events were reported from participants (3/25, 12%) in the GA 35-42 weeks PNA <14 days group. These participants had creatinine levels of 1.07 mg/dL, 2.03 mg/dL and 1.92 mg/dL on the day of the renal failure event, and none of them required dialysis.

Participants from ▬ reported the highest incidence of hypotension (5/13, 38%) events. ▬ was the site that reported the highest incidence of intraventricular hemorrhage (3/9, 33%) events and ▬ had the highest incidence of rash events (11/20, 55%). For all diagnosis AEs with >1 event, the dose response analysis shows the median maximum doses (mg/kg/day) for participants without events were greater than or equal to the median maximum dose for participants with events (Table 14.2.1.3.1).

Table 12-2 Diagnosis AEs by GA and PNA group

| GA 23-29 weeks; (N=6) | GA 30-34 weeks; (N=10) | GA 35-42 weeks; PNA <14 days; (N=25) | GA 35-42 weeks; PNA >=14 days; (N=8) | Total; (N=49)
Rash
Number of Events | 3 | 6 | 11 | 1 | 21
Number of Participants | 3 (50.0%) | 6 (60.0%) | 8 (32.0%) | 1 (12.5%) | 18 (36.7%)
Hypotension
Number of Events | 3 | 2 | 15 | 0 | 20
Number of Participants | 2 (33.3%) | 2 (20.0%) | 8 (32.0%) | 0 | 12 (24.5%)
Seizure
Number of Events | 0 | 2 | 3 | 4 | 9
Number of Participants | 0 | 1 (10.0%) | 3 (12.0%) | 3 (37.5%) | 7 (14.3%)
Intraventricular Hemorrhage
Number of Events | 1 | 1 | 0 | 2 | 4
Number of Participants | 1 (16.7%) | 1 (10.0%) | 0 | 2 (25.0%) | 4 (8.2%)
Renal Failure
Number of Participants | 0 | 0 | 3 (12.0%) | 0 | 3 (6.1%)
PDA Requiring Surgical Treatment
Number of Participants | 1 (16.7%) | 0 | 0 | 0 | 1 (2.0%)

There were 13 severe diagnosis neurologic AEs reported in 9 (18%) participants: 4 (8%) participants with Grade III or IV intraventricular hemorrhage and 7(14%) with seizure.

Twenty mild diagnosis cardiovascular events (hypotension) were reported in 12 (25%) participants and 1(2%) severe event (PDA requiring surgical treatment). Three severe nephrology events (renal failure) were reported in 3 (6%) participants and they were all in the GA 35-42 weeks PNA <14 days group.

Mild dermatologic event was the most frequently reported type of diagnosis AE. Twenty-one mild dermatologic events (rash) were reported in 18 (37%) participants.

Table 12-3 Diagnosis AEs by Body System, GA and PNA Group

| GA 23-29 weeks; (N=6) | | GA 30-34 weeks; (N=10) | | GA 35-42 weeks; PNA <14 days; (N=25) | | GA 35-42 weeks; PNA >=14 days; (N=8) | | Total; (N=49)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Neurologic
Number of Events | 0 | 1 | 0 | 3 | 0 | 3 | 0 | 6 | 0 | 13
Number of Participants | 0 | 1 (16.7%) | 0 | 2 (20.0%) | 0 | 3 (12.0%) | 0 | 3 (37.5%) | 0 | 9 (18.4%)
Cardiovascular
Number of Events | 3 | 1 | 2 | 0 | 15 | 0 | 0 | 0 | 20 | 1
Number of Participants | 2 (33.3%) | 1 (16.7%) | 2 (20.0%) | 0 | 8 (32.0%) | 0 | 0 | 0 | 12 (24.5%) | 1 (2.0%)
Nephrology
Number of Events | N/A | 0 | N/A | 0 | N/A | 3 | N/A | 0 | N/A | 3
Number of Participants | N/A | 0 | N/A | 0 | N/A | 3 (12.0%) | N/A | 0 | N/A | 3 (6.1%)
Dermatologic
Number of Events | 3 | N/A | 6 | N/A | 11 | N/A | 1 | N/A | 21 | N/A
Number of Participants | 3 (50%) | N/A | 6 (60.0%) | N/A | 8 (32.0%) | N/A | 1 (12.5%) | N/A | 18 (36.7%) | N/A

#### 12.2.1.3 Laboratory AEs

An overall summary (number of events, events per day per participant and number of participants) of laboratory AEs by severity and either GA and PNA group or site is presented in Tables 14.2.2.1.1, 14.2.2.1.2, 14.2.2.2.1, 14.2.2.2.2, 14.2.2.3.1 to 14.2.2.3.16 and 12-4.

The participants in the GA 23-29 weeks group reported the highest mild laboratory AE rates in serum electrolytes (4/6, 67%), renal dysfunction (3/6, 50%) and complete blood count (5/6, 83%). Participants in the GA 35-42 weeks PNA <14 days group had the highest mild (18/25, 72%) and severe (12/25, 48%) liver dysfunction AEs. Participants from ▬ reported the highest mild serum electrolytes (9/13, 69%) AE rates and had higher AE rates of mild (10/13, 77%) and severe (9/13, 69%) liver dysfunction. Comparing for participants with and without events, higher median maximum doses (mg/kg/day) prior to the events were reported for hypokalemia (96 vs 64), elevated BUN (96 vs 65) and thrombocytosis (110 vs 71); the median maximum doses for participants without events were higher or equal to the median of maximum dose prior to events for the participants with events for all other laboratory AEs.

Table 12-4 Laboratory AEs by Laboratory Test, GA and PNA Group and Severity

| GA 23-29 weeks; (N=6) | | GA 30-34 weeks; (N=10) | | GA 35-42 weeks; PNA <14 days; (N=25) | | GA 35-42 weeks; PNA >=14 days; (N=8) | | Total; (N=49)
| Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe | Mild | Severe
Serum Electrolytes
Number of Events | 21 | 2 | 12 | 2 | 40 | 4 | 9 | 0 | 82 | 8
Number of Participants | 4 (66.7%) | 1 (16.7%) | 5 (50.0%) | 1 (10.0%) | 14 (56.0%) | 3 (12.0%) | 3 (37.5%) | 0 | 26 (53.1%) | 5 (10.2%)
Renal Dysfunction
Number of Events | 18 | 4 | 8 | 0 | 14 | 1 | 1 | 0 | 41 | 5
Number of Participants | 3 (50.0%) | 1 (16.7%) | 2 (20.0%) | 0 | 5 (20.0%) | 1 (4.0%) | 1 (12.5%) | 0 | 11 (22.4%) | 2 (4.1%)
Liver Dysfunction
Number of Events | 5 | 1 | 23 | 14 | 72 | 53 | 20 | 10 | 120 | 78
Number of Participants | 1 (16.7%) | 1 (16.7%) | 3 (30.0%) | 4 (40.0%) | 18 (72.0%) | 12 (48.0%) | 4 (50.0%) | 1 (12.5%) | 26 (53.1%) | 18 (36.7%)
Complete Blood Count
Number of Events | 26 | 0 | 12 | 0 | 95 | 3 | 21 | 0 | 154 | 3
Number of Participants | 5 (83.3%) | 0 | 5 (50.0%) | 0 | 16 (64.0%) | 3 (12.0%) | 3 (37.5%) | 0 | 29 (59.2%) | 3 (6.1%)

Eighty-two mild serum electrolytes AEs were reported in 26 (53%) participants: hyperglycemia in 17 (35%), hypoglycemia in 1 (2%), hypernatremia in 2 (4%), hyponatremia in 6 (12%), hyperkalemia in 5 (10%) and hypokalemia in 9 (18%) participants. Eight severe serum electrolytes AEs were reported in 5 (10%) participants: hyperglycemia 2 (4%), hypernatremia 1 (2%) and hyperkalemia 3 (6%).

Forty-one mild renal dysfunction AEs were reported in 11 (22%) participants: elevated BUN in 4 (8%) and elevated creatinine in 10 (20%) participants. Five severe renal dysfunction AEs were reported in 2 (4%) participants: elevated BUN 1 (2%) and elevated creatinine 1 (2%).

One hundred and twenty mild liver dysfunction AEs were reported in 26 (53%) participants: elevated AST 11 (22%), elevated ALT 18 (37%), elevated GGT 11 (22%) and direct bilirubin 12 (24%). Seventy-eight severe liver dysfunction AEs were reported in 18 (37%) participants: elevated AST 14 (29%), elevated ALT 10 (20%), elevated GGT 5 (10%) and direct bilirubin 4 (8%). Mild elevated ALT and severe elevated AST are the most frequently reported liver dysfunction AEs.

Mild complete blood count AE was the most frequently reported laboratory AE. One hundred and fifty-four mild complete blood count AEs reported in 29 (59%) participants: leukocytosis 1 (2%), leukopenia 14 (29%), thrombocytosis 5 (10%) and thrombocytopenia 21 (43%). Three severe complete blood count AEs (thrombocytopenia) were reported in 3 (6%) participants.

### 12.2.2 Positive HSV Diagnostic Tests

Type and findings of positive HSV diagnostic tests collected at baseline and the end of study (last recorded positive HSV diagnostic test) are summarized in Tables 14.2.3.1.1, 14.2.3.1.2, 14.2.3.2.1 and 14.2.3.2.2. Thirty-nine (39/49, 80%) participants had positive diagnostic tests reported at baseline (participant may report multiple positive tests); the other ten (10/49, 20%) participants not presented in this section include 1 with suspected HSV diagnostic test and 9 with the first positive HSV diagnostic test reported after the first study dose. Among the 39 participants with positive diagnostic tests at baseline, 9 participants had positive HSV viral cultures, 32 had HSV DNA PCR and 1 had HSV direct immunofluorescence assay. Positive HSV diagnostic test findings were 7 participants with HSV of unspecified type, 13 HSV type 1 and 21 HSV type 2. Number of participants with positive HSV diagnostic tests decreased at the end of study. There were 8 (16%) participants that had positive tests at the end of study. There were 3 participants with positive HSV viral cultures and 5 participants with positive HSV DNA PCR. Positive diagnostic test results were 1 HSV of unspecified type, 1 HSV type 1 and 6 HSV type 2.

### 12.2.3 Summary of Safety and Laboratory Toxicity Results

An overall summary of safety and laboratory toxicity for selected diagnosis AEs (death, seizure and renal failure) and laboratory AEs (elevated BUN, elevated creatinine and leukopenia) is presented in Tables 14.2.1.3.1 to 14.2.1.3.7, 14.2.2.3.1 to 14.2.2.3.16 and 12-5.

The participants in the GA 23-29 weeks group reported the highest event rates in death (2/6, 33%), elevated BUN (1/6, 17%) and elevated creatinine (3/6, 50%) among all GA and PNA groups. The participants in the GA 35-42 weeks & PNA <14 days reported the highest leukopenia event rate (10/25, 40%) and all 3 renal failure events(3/25, 12%) among all GA and PNA groups. The participants in the GA 35-42 weeks & PNA ≥14 days had the highest seizure event rate (3/8, 38%) among all GA and PNA groups.

The participants in the PMA <30 weeks reported the highest event rates in death (2/5, 40%) and elevated BUN (1/5, 20%) among all PMA groups. The participants in the PMA 30-35 weeks had the highest event rates in seizure (1/7, 14%) and elevated creatinine (3/7, 43%) among all PMA groups. The participants in the PMA >35 weeks reported the highest leukopenia event rate (11/36, 31%) and all 3 renal failure events (3/36, 8%) among all PMA groups.

The Maximum Dose is defined as maximum daily IV dose up to the day of the event for participants with an event and maximum daily IV dose while on study acyclovir for participants without an event during the study period. Among all Maximum Dose groups, the participants in the lowest dose group (<50 mg/kg/day) reported the highest event rates in seizure (2/5, 40%), leukopenia (2/4, 50%) and all 3 death events (3/3, 100%). The participants in the 50-70 mg/kg/day dose group had the highest elevated creatinine event rate (7/21, 33%) and all 3 renal failure events (3/21, 14%) among all Maximum Dose groups. The participants in the highest dose group (>70 mg/kg/day) had the highest elevated BUN event rate (3/25, 12%) among all Maximum Dose groups.

Overall, the participants with serum creatinine level greater than 1.2 mg/dL at their baseline visit had higher event rates of death (3/6, 50%), seizure (2/6, 33%), renal failure (1/6, 17%), elevated BUN (2/6, 33%), elevated creatinine (3/6, 50%) and leukopenia (2/6, 33%) than participants with a serum creatinine level lower than 1.2 mg/dL.

The participants with an HSV positive blood specimen at baseline reported highest event rates in death (5/11, 46%) and seizure (2/11, 18%). The participants with HSV positive SEM specimen at baseline had highest event rates in renal failure (2/14, 14%), elevated BUN (3/14, 21%), elevated creatinine (5/14, 36%) and leukopenia (5/14, 36%).

Table 12-5 Summary of Safety and Laboratory Toxicity Results

| Diagnosis AEs | | | Laboratory AEs
| Death; (N=9) | Seizure; (N=7) | Renal Failure; (N=3) | Elevated BUN; (N=4) | Elevated Creatinine; (N=10) | Leukopenia; (N=14)
GA and PNA Group
GA 23-29 Weeks (N=6) | 2 (33.3%) | 0 | 0 | 1 (16.7%) | 3 (50.0%) | 0
GA 30-34 Weeks (N=10) | 2 (20.0%) | 1 (10.0%) | 0 | 0 | 2 (20.0%) | 2 (20.0%)
GA 35-42 weeks&PNA <14 days (N=25) | 5 (20.0%) | 3 (12.0%) | 3 (12.0%) | 2 (8.0%) | 5 (20.0%) | 10 (40.0%)
GA 35-42 weeks&PNA >=14 days (N=8) | 0 | 3 (37.5%) | 0 | 1 (12.5%) | 0 | 2 (25.0%)
PMA Group
PMA <30 Weeks (N=5) | 2 (40.0%) | 0 | 0 | 1 (20.0%) | 2 (40.0%) | 0
PMA 30-35 Weeks (N=7) | 2 (28.6%) | 1 (14.3%) | 0 | 0 | 3 (42.9%) | 2 (28.6%)
PMA >35 Weeks (N=36) | 5 (13.9%) | 5 (13.9%) | 3 (8.3%) | 3 (8.3%) | 5 (13.9%) | 11 (30.6%)
Not Reported (N=1) | 0 | 1 (100.0%) | 0 | 0 | 0 | 1 (100.0%)
Maximum Dose (mg/kg/day)
<50 | 3/3 (100.0%) | 2/5 (40.0%) | 0/3 | 0/3 | 0/3 | 2 /4 (50.0%)
50-70 | 6/21 (28.6%) | 2/19 (10.5%) | 3 /21(14.3%) | 1/21 (4.8%) | 7/21 (33.3%) | 10 /23 (43.5%)
>70 | 0 | 3/25 (12.0%) | 0/25 | 3/25 (12.0%) | 3/25 (12.0%) | 2 /22 (9.1%)
Baseline Serum Creatinine (mg/dL)
<=1.2 (N=42) | 5 (11.9%) | 5 (11.9%) | 2 (4.8%) | 2 (4.8%) | 7 (16.7%) | 12 (28.6%)
>1.2 (N=6) | 3 (50.0%) | 2 (33.3%) | 1 (16.7%) | 2 (33.3%) | 3 (50.0%) | 2 (33.3%)
Not Reported (N=1) | 1 (100.0%) | 0 | 0 | 0 | 0 | 0
Positive HSV Specimen
Blood (N=11) | 5 (45.5%) | 2 (18.2%) | 0 | 0 | 1 (9.1%) | 2 (18.2%)
Cerebrospinal Fluid (N=14) | 1 (7.1%) | 2 (14.3%) | 0 | 0 | 1 (7.1%) | 3 (21.4%)
SEM (N=14) | 2 (14.3%) | 1 (7.1%) | 2 (14.3%) | 3 (21.4%) | 5 (35.7%) | 5 (35.7%)
Unknown (N=10) | 1 (10.0%) | 2 (20.0%) | 1 (10.0%) | 1 (10.0%) | 3 (30.0%) | 4 (40.0%)

## 12.3 Safety Conclusions

In this critically ill cohort of infants, mortality was high (18%) and was highest among the most immature infants, 23-29 weeks GA (33%). Rash was the most common diagnostic AE reported (37%). Elevated liver enzymes were the most commonly reported laboratory AEs. Dose amount was not related to occurrence of diagnostic AEs. Many of the AEs may be related to the underlying illness (e.g., rash, hypotension, seizure, elevated liver enzymes).