# 11 EFFICACY EVALUATION

Efficacy analyses were not performed as part of this protocol.